# INTRODUCTION

Venous thromboembolic (VTE) events are important causes of morbidity in elective total hip replacement (THR) and total knee replacement (TKR) procedures, which are being performed with increasing frequency in an aging population. Because of the substantial risk of VTE, current guidelines recommend thromboprophylaxis in patients undergoing THR or TKR.1–3 Low molecular weight heparin (LMWH) and adjusted-dose warfarin are the most commonly used anticoagulants for thromboprophylaxis in the United States,4 but a number of pharmacological treatment options are available including unfractionated heparin, aspirin, and newer oral anticoagulants. These drug classes differ in practical applications such as a predictable dose-response and the need for laboratory monitoring, oral versus injection administration, dosing frequency, drug-drug interactions, and the availability of an appropriate reversal mechanism in case of over anticoagulation. In addition, mechanical thromboprophylaxis, most frequently used in combination with anticoagulants, is commonly used in the United States.

Risk factors for VTE include venous stasis, endothelial injury, and hypercoagulability. Venous stasis can result from the positioning of the limb, localized postoperative swelling, or limited mobility in the postoperative period.5,6 Endothelial injury can result from positioning and manipulation of the limb.5,7 Markers of thrombin generation, indicating hypercoagulability, have been shown to be elevated in total hip arthroplasty.8 Prior to 1980, rates of symptomatic VTE were 15 to 30 percent. However, changes in surgical care, including earlier ambulation, and changes to surgical technique that are less invasive and possibly less thrombogenic have decreased the rate of symptomatic VTE. A recent analysis that incorporated data from trials and observational studies estimated the contemporary 35-day rate of symptomatic VTE without thromboprophylaxis at 4.3 percent.1

Pharmacological thromboprophylaxis for THR or TKR surgery decreases VTE by approximately 50 percent but with the tradeoff of increased bleeding.9 Surgical procedures may also increase bleeding risk; major bleeding is estimated to occur in 1.5 percent of patients undergoing THR or TKR, even without thromboprophylaxis.1 The risk of bleeding is a concern because bleeding can lead to infections, reoperation, delayed wound healing, and extended hospital stay.10 Considering both benefits and risks, guideline panels have issued moderate to strong recommendations for thromboprophylaxis in patients without a contraindication.1–3 The choice of which antithrombotic thus becomes pivotal for balancing the prevention of thromboembolism with the risk of bleeding.

## PHARMACOLOGICAL TREATMENT OPTIONS FOR VTE THROMBOPROPHYLAXIS

The most commonly used anticoagulants are LMWH, fondaparinux, and warfarin.4,11,12 Unfractionated heparin and antiplatelet agents are rarely used. The efficacy and safety of LMWH for postoperative thromboprophylaxis has been established in more than 30 studies.3,9,13 LMWH binds to antithrombin and accelerates the inhibition of thrombin and factor X. LMWH has a long half-life, which allows a once-daily dosing schedule and good bioavailability after subcutaneous injection. Disadvantages of LMWH include the need for parenteral administration, high drug cost, and a small risk of heparin-induced thrombocytopenia.14 Similarly, fondaparinux has good bioavailability when given once daily subcutaneously. Due to the length of the molecule, fondaparinux mainly acts by catalyzing the inhibition of factor Xa (FXa) with essentially no inhibition of thrombin.15

For nearly 50 years, warfarin has been successfully used for prophylaxis and treatment of VTE. Warfarin is administered orally once daily and is inexpensive. However, it has several disadvantages, including the need for regular monitoring with international normalized ratio (INR) and numerous interactions with a host of drugs, herbs, and dietary products. Its delayed onset of action can leave patients unprotected in the early postoperative period. In fact, registry data show that surgeons using warfarin are less likely to meet guideline recommendations than with other agents due to failure to meet the target INR.4

Newer oral anticoagulants have been developed with the goal to overcome the limitations of warfarin and the available parenteral agents. These new anticoagulants belong to two drug classes, based on their target coagulation protein: FXa inhibitors and direct thrombin inhibitors (DTIs). These are given as fixed oral doses and have the advantage of a more predictable anticoagulant effect, eliminating the need for monitoring when used for short term thromboprophylaxis. Disadvantages of newer oral anticoagulants include drug costs and the lack of specific antidotes to reverse their anticoagulant effect in a timely fashion in case of bleeding. Rivaroxaban, an oral FXa inhibitor, was approved on July 1, 2011, by the U.S. Food and Drug Administration (FDA) for prophylaxis of VTE in adults undergoing orthopedic surgery. Other oral FXa inhibitors that are currently under clinical development include apixaban, edoxaban, and betrixaban. Apixaban is under FDA review for thromboprophylaxis in orthopedic surgery. Dabigatran etexilate is an oral DTI that has been approved in the United States for stroke prevention in atrial fibrillation. Renal excretion is the predominant elimination pathway for dabigatran, with more than 80 percent of systemically available dabigatran eliminated unchanged.16 Dabigatran has a better drug interaction profile compared with warfarin and is currently under review for FDA approval in patients undergoing elective orthopedic surgery.

Given the emerging data on new oral anticoagulants, this report was commissioned by the VA to assess the comparative effectiveness of newer oral anticoagulants and standard thromboprophylaxis regimens in total hip and knee replacement surgery.