# SAMPLE DATA ABSTRACTION FORM

First author, year, Reference Library#

STATED OBJECTIVE OF PAPER: “ ”

METHODS:

[underlined: Databases accessed for literature search]: X, Y, Z… and abstracts of (meetings, Websites, etc.):

[underlined: Search date]:

[underlined: Language limits for search]:

[underlined: Inclusion criteria]: Cut and paste from article AND ensure the following are addressed:

- Study design type:
- Patients: Any characteristic that would include or exclude (e.g., under 18 years)
- Intervention: Drugs of interest
- Comparator: What is considered a valid comparator for the drug of interest?
- Outcomes: Any of the following (also provide any definitions given by the authors):
  1. All-cause mortality
  2. VTE-related mortality
  3. VTE (only if DVT and PE not given separately)
  4. Symptomatic DVT
  5. Nonfatal PE
  6. Serious AEs
  7. Fatal bleeding
  8. Major bleeding
  9. Bleeding from the surgical site
  10. Rehospitalization (includes bleeding that requires reoperation).

[underlined: Exclusion criteria]: Cut and paste from article

[underlined: Summary of analysis approach]:

- System used (RevMan, Peto, CMA, etc.)
- Report statistic (OR, RR, RD, MD, combination?)
- Special procedures (double-checking, etc.)
- Heterogeneity addressed?
- Publication bias addressed?
- Subgroup analyses?
- Sensitivity analyses?

[underlined: Funding Source]: Look carefully for pharma $

QUALITY: See separate quality rating form

RESULTS: Number of key questions: XX (if multiple KQs, complete this section for each KQ)

[underlined: A. Number of studies included] (if numbers vary by KQ, give total and number for each KQ): XX met eligibility; XX analyzed (were any articles specific excluded, why?)

[underlined: B. Patient characteristics (range across studies):]

Type of surgery: Knee replacement (n=); hip replacement (n=); either knee or hip (n=)

Sex (female-n %): ---- to ---- (XX.X to XX.X%)

Sample size (n): YY to YY, YYY

Mean age (years): ZZ.Z to ZZ.Z

Mean BMI or weight: AA.A to AA.A

Veteran settings, if given:

Risk factors for bleeding (prior GI bleed, anemia, renal insufficiency, DM):

Intervention drugs: (generic name, number of studies, notes about dosage)

1. KQ1 – newer oral anticoagulants (FXa or DTI)
2. KQ2 – combined pharmacological (any type) + mechanical modalities
3. KQ3 – new oral anticoagulant (FXa or DTI)

Comparator:

1. KQ1 – LMWH, UFH, warfarin, aspirin
2. KQ2 – pharmacological treatment alone
3. KQ3 – other newer oral anticoagulant (FXa or DTI) – direct or indirect comparison

Concurrent other drug administration? (yes/no)

- Antiplatelet drugs:
- Other

[underlined: C. Outcomes]: (FXa vs LMWH)

Outcomes definition:

- Were they objectively evaluated?
- Was there missing data?
- Other specifics mentioned about quality of results:

Duration of anticoagulation:

- Knee: e.g., 5–14 days (n=)
  - ≥15 days (n=)
- Hip: e.g., < 28 days (n=)
  - ≥ 28 days (n=)

Followup timing:

- e.g., <14 days (n=)
- 14–30 days (n=)
- > 30 days (n=)

Risk of bias for primary studies: Any standard ratings given? Specific issues? (e.g., blinding? adjudication? poor completion rates?)

Quantitative summaries: Give # participants, # studies, summary estimate and 95% CI, I^2^, RD (per 1,000), strength of evidence (SOE) if given. [For example: 22,838 participants, 11 studies; OR 0.95 (95% CI, 0.55 to 1.63); I^2^=43%; RD=0 fewer events (CI, 2 fewer to 1 more) per 1,000; SOE=High]

Provide these data for the following outcomes, if given:

- [underlined: Mortality]:
- [underlined: VTE-related mortality]:
- [underlined: Total VTE]:
- [underlined: Symptomatic DVT]:
- [underlined: Nonfatal PE]:
- [underlined: Serious AEs]:
- [underlined: Major bleeding]:
- [underlined: Bleeding from the surgical site]:
- [underlined: Rehospitalization]: (give reason if possible)
- [underlined: Other outcome of significance]:

Did they measure publication bias? (via funnel plots, etc.)

Subgroup analyses: If presented, give type and outcome

- Dose:
- Type of surgery:
- Within drug class:
- Multiple treatments:

Sensitivity analysis: If presented, give type and outcome

AUTHOR’S CONCLUSION: (take-home message): “ ”