# SEARCH STRATEGIES

Table A-1 Search strategy for PubMed (5/29/2012, updated 9/28/2012)

Set # | Terms | Results
1 | Dabigatran[tiab] OR desirudin[tiab] OR edoxaban[tiab] OR rivaroxaban[tiab] OR apixaban[tiab] OR betrixaban[tiab] OR YM150[tiab] OR razaxaban[tiab] OR “dabigatran etexilate”[Supplementary Concept] OR “desirudin”[Supplementary Concept] OR “edoxaban”[Supplementary Concept] OR “rivaroxaban”[Supplementary Concept] OR “apixaban”[Supplementary Concept] OR “betrixaban”[Supplementary Concept] OR “razaxaban hydrochloride”[Supplementary Concept] OR “factor Xa, Glu-Gly-Arg-”[Supplementary Concept] OR “KFA1411”[Supplementary Concept] | 1319
2 | (((knee[tiab] OR hip[tiab] OR elbow[ti]) AND (replacement[tiab] OR Arthroplasty[tiab]))) OR (“Orthopedic Procedures”[Mesh]) | 194066
3 | #1 AND #2 | 298
4 | (“Review”[Publication Type] OR “Review Literature as Topic”[Mesh]) OR (“Meta-Analysis as Topic”[Mesh] OR “Meta-Analysis”[Publication Type]) OR systematic[sb] | 1782948
5 | #3 AND #4 | 117

Table A-2 Search strategy for Embase (5/30/2012, updated 9/28/2012)

Set # | Terms | Results
1 | ‘dabigatran’/exp OR dabigatran OR ‘desirudin’/exp OR desirudin OR ‘edoxaban’/exp OR edoxaban OR ‘rivaroxaban’/exp OR rivaroxaban OR ‘apixaban’/exp OR apixaban OR’betrixaban’/exp OR betrixaban OR ‘ym150’/exp OR ym150 OR ‘razaxaban’/exp OR razaxaban OR ‘factor xa inhibitors’ OR ‘factor xa inhibitor’/exp OR ‘factor xa inhibitor’ OR ‘fxa inhibitors’ OR ‘fxa inhibitor’ OR’direct thrombin inhibitor’ OR ‘direct thrombin inhibitors’ OR dtis OR ‘novel anticoagulants’ OR ‘new anticoagulants’ OR ‘novel anticoagulant’ OR ‘new anticoagulant’ | 10942
2 | ‘orthopedic surgery’/exp OR (hip:ab,ti OR knee:ab,ti OR elbow:ab,ti AND (replacement:ab,ti OR arthroplasty:ab,ti)) | 351,364
3 | #1 AND #2 | 1522
4 | #3 limited to Systematic reviews or meta –analysis AND (embase)/lim NOT (medline)/lim | 43

Table A-3 Search strategy for Cochrane Database of Systematic Reviews (5/30/2012, updated 9/28/2012)

Set # | Term | Results
1 | dabigatran OR desirudin OR edoxaban OR rivaroxaban OR apixaban OR betrixaban OR YM150 OR razaxaban OR “factor Xa inhibitors” OR “factor Xa inhibitor” OR “fxa inhibitors” OR “fxa inhibitor” OR “direct thrombin inhibitor” OR “direct thrombin inhibitors” OR DTIs OR “novel anticoagulants” OR “new anticoagulants” OR “novel anticoagulant” OR “new anticoagulant” | 472
2 | MeSH descriptor Orthopedic Procedures explode all trees OR (knee):ti,ab,kw or (elbow):ti,ab,kw) AND (replacement):ti,ab,kw or (arthroplasty):ti,ab,kw | 8138
3 | #1 AND #2 | 117
4 | #3 limited to Systematic reviews or meta-analysis | 8