# REFERENCES

1 Ansell J, Hirsh J, Hylek E, et al. Pharmacology and management of the vitamin K antagonists: American College of Chest Physicians Evidence-Based Clinical Practice Guidelines (8th Edition). Chest. 2008;133(6 Suppl):160S-98S. [pmid: 18574265].
2 Connock M, Stevens C, Fry-Smith A, et al. Clinical effectiveness and cost-effectiveness of different models of managing long-term oral anticoagulation therapy: a systematic review and economic modelling. Health Technology Assessment (Winchester, England). 2007;11(38):iii-iv.
3 Review Manager (RevMan) [Computer program]. Version 5.0 for Windows. Copenhagen. The Nordic Cochrane Centre, The Cochrane Collaboration. 2008.
4 Higgins JP, Thompson SG, Deeks JJ, Altman DG. Measuring inconsistency in meta-analysis. BMJ. 2003;327:557-60. [pmid: 12958120].
5 Egger M, Davey Smith G, Schneider M, Minder C. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315:629-34. [pmid: 9310563].
6 Wilson SJ, Wells PS, Kovacs MJ, et al. Comparing the quality of oral anticoagulant management by anticoagulation clinics and by family physicians: a randomized controlled trial. CMAJ. 2003;169(4):293-8. [pmid: 12925422].
7 Chan FW, Wong RS, Lau WH, et al. Management of Chinese patients on warfarin therapy in two models of anticoagulation service - a prospective randomized trial. Br J Clin Pharmacol. 2006;62(5):601-9. [pmid: 17061966].
8 Matchar DB, Samsa GP, Cohen SJ, et al. Improving the quality of anticoagulation of patients with atrial fibrillation in managed care organizations: results of the managing anticoagulation services trial. Am J Med. 2002;113(1):42-51. [pmid: 12106622].
9 Lee YP, Schommer JC, Lee YP, et al. Effect of a pharmacist-managed anticoagulation clinic on warfarin-related hospital readmissions. Am JHealth-Syst Pharm. 1996;53(13):1580-3. [pmid: 8809280].
10 Chiquette E, Amato MG, Bussey HI, et al. Comparison of an anticoagulation clinic with usual medical care: anticoagulation control, patient outcomes, and health care costs. Arch Intern Med. 1998;158(15):1641-7. [pmid: 9701098].
11 Chamberlain MA, Sageser NA, Ruiz D, et al. Comparison of anticoagulation clinic patient outcomes with outcomes from traditional care in a family medicine clinic. J Am Board Fam Pract. 2001;14(1):16-21. [pmid: 11206689].
12 Witt DM, Sadler MA, Shanahan RL, et al. Effect of a centralized clinical pharmacy anticoagulation service on the outcomes of anticoagulation therapy. Chest. 2005;127(5):1515-22. [pmid: 15888822].
13 Nichol MB, Knight TK, Dow T, et al. Quality of anticoagulation monitoring in nonvalvular atrial fibrillation patients: comparison of anticoagulation clinic versus usual care. Ann Pharmacother. 2008;42(1):62-70. [pmid: 18094348].
14 Du X, Ma CS, Liu XH, et al. Anticoagulation control in atrial fibrillation patients present to outpatient clinic of cardiology versus anticoagulant clinics. Chin Medl J. 20. 2005;118(14):1206-9.
15 Wallvik J, Sjalander A, Johansson L, et al. Bleeding complications during warfarin treatment in primary healthcare centres compared with anticoagulation clinics. Scand J Prim Health Care. 2007;25(2):123-8. [pmid: 17497491].
16 Ansell J, Hollowell J, Pengo V, et al. Descriptive analysis of the process and quality of oral anticoagulation management in real-life practice in patients with chronic non-valvular atrial fibrillation: the international study of anticoagulation management (ISAM). J Thromb Thrombolysis. 2007;23(2):83-91. [pmid: 17221328].
17 Matchar DM, Jacobson A, Dolor R, et al., for the THINRS Executive Committee and Site Investigators. Effect of home testing of international normalized ratio on clinical events. N Engl J Med. 2010;363(17):1608-1620. [pmid: 20961244].
18 Beyth RJ, Quinn L, Landefeld CS. A multicomponent intervention to prevent major bleeding complications in older patients receiving warfarin. A randomized, controlled trial. Ann Intern Med. 2000;133(9):687-95. [pmid: 11074901].
19 Sunderji R, Gin K, Shalansky K, et al. A randomized trial of patient self-managed versus physician-managed oral anticoagulation. Can J Cardiol. 2004;20(11):1117-23. [pmid: 15457308].
20 Sawicki PT. A structured teaching and self-management program for patients receiving oral anticoagulation: a randomized controlled trial. Working Group for the Study of Patient Self-Management of Oral Anticoagulation. JAMA. 1999;281(2):145-50. [pmid: 9917117].
21 Cromheecke ME, Levi M, Colly LP, et al. Oral anticoagulation self-management and management by a specialist anticoagulation clinic: a randomised cross-over comparison. Lancet. 2000;356(9224):97-102. [pmid: 10963245].
22 Fitzmaurice DA, Murray ET, Gee KM, et al. A randomised controlled trial of patient self management of oral anticoagulation treatment compared with primary care management. J Clin Pathol. 2002;55(11):845-9. [pmid: 12401823].
23 Gadisseur AP, Breukink-Engbers WG, van der Meer FJ, et al. Comparison of the quality of oral anticoagulant therapy through patient self-management and management by specialized anticoagulation clinics in the Netherlands: a randomized clinical trial. Arch Intern Med. 2003;163(21):2639-46. [pmid: 14638565].
24 Gadisseur AP, Kaptein AA, Breukink-Engbers WG, et al. Patient self-management of oral anticoagulant care vs. management by specialized anticoagulation clinics: positive effects on quality of life. J Thromb Haemost. 2004;2(4):584-91. [pmid: 15102012].
25 Khan TI, Kamali F, Kesteven P, et al. The value of education and self-monitoring in the management of warfarin therapy in older patients with unstable control of anticoagulation. Br J Haematol. 2004;126(4):557-64. [pmid: 15287950].
26 Gardiner C, Williams K, Mackie IJ, et al. Patient self-testing is a reliable and acceptable alternative to laboratory INR monitoring. Br J Haematol. 2005;128(2):242-7. [pmid: 15638860].
27 Voller H, Glatz J, Taborski U, et al. Self-management of oral anticoagulation in nonvalvular atrial fibrillation (SMAAF study). Zeitschrift fur Kardiologie. 2005;94(3):182-6. [pmid: 15747040].
28 Christensen TD, Maegaard M, Sorensen HT, et al. Self-management versus conventional management of oral anticoagulant therapy: A randomized, controlled trial. Eur J Intern Med. 2006;17(4):260-6. [pmid: 16762775].
29 Christensen TD, Maegaard M, Sorensen HT, et al. Self- versus conventional management of oral anticoagulant therapy: effects on INR variability and coumarin dose in a randomized controlled trial. Am J Cardiovasc Drugs. 2007;7(3):191-7. [pmid: 17610346].
30 Gardiner C, Williams K, Longair I, et al. A randomised control trial of patient self-management of oral anticoagulation compared with patient self-testing. Br J Haematol. 2006;132(5):598-603. [pmid: 16445833].
31 Dauphin C, Legault B, Jaffeux P, et al. Comparison of INR stability between self-monitoring and standard laboratory method: preliminary results of a prospective study in 67 mechanical heart valve patients. Arch Cardiovasc Dis. 2008;101(11-12):753-61. [pmid: 19059570].
32 Ryan F, Byrne S, O'Shea S. Randomized controlled trial of supervised patient self-testing of warfarin therapy using an internet-based expert system. J Thromb Haemost. 2009;7:1284-90. [pmid: 19496921].
33 Horstkotte D, Piper C, Wiemer M, et al. Improvement of prognosis by home prothrombin estimation in patients with life-long anticoagulation therapy. Abstract. Eur Heart J. 1996;17(Suppl):230. [pmid: 8732376].
34 Horstkotte D, Piper C, Wiemer M. Optimal Frequency of Patient Monitoring and Intensity of Oral Anticoagulation Therapy in Valvular Heart Disease. J Thromb Thrombolysis. 1. 1998;5(3):19-24. [pmid: 10767128].
35 Koertke H, Minami K, Breymann T, et al. INR Self-management after mechanical heart faclve replacement: ESCAT (Early Self-Controlled Anticoagulation Trial). Z Cardiol. 2001;90(Suppl 6):V1/118-124.
36 Koertke H, Korfer R. International normalized ratio self-management after mechanical heart valve replacement: is an early start advantageous?. Ann Thorac Surg. 2001;72(1):44-8. [pmid: 11465228].
37 Koertke H, Zittermann A, Wagner O, et al. Self-management of oral anticoagulation therapy improves long-term survival in patients with mechanical heart valve replacement. AnnThorac Surg. 2007;83(1):24-9.
38 Sidhu P, O'Kane HO. Self-managed anticoagulation: results from a two-year prospective randomized trial with heart valve patients. Ann Thorac Surg. 2001;72(5):1523-7. [pmid: 11722037].
39 Fitzmaurice DA, Murray ET, McCahon D, et al. Self management of oral anticoagulation: randomised trial. BMJ. 2005;331(7524):1057. [pmid: 16216821].
40 Jowett S, Bryan S, Murray E, et al. Patient self-management of anticoagulation therapy: a trial-based cost-effectiveness analysis. Br J Haematol. 2006;134(6):632-9. [pmid: 16938120].
41 Menendez-Jandula B, Souto JC, Oliver A, et al. Comparing self-management of oral anticoagulant therapy with clinic management: a randomized trial. Ann Intern Med. 2005;142(1):1-10. [pmid: 15630104].
42 Siebenhofer A, Rakovac I, Kleespies C, et al. Self-management of oral anticoagulation in the elderly: rationale, design, baselines and oral anticoagulation control after one year of follow-up. A randomized controlled trial. Thromb Haemost. 2007;97(3):408-16. [pmid: 17334508].
43 Siebenhofer A, Rakovac I, Kleespies C, et al. Self-management of oral anticoagulation reduces major outcomes in the elderly. A randomized controlled trial. Thromb Haemost. 2008;100(6):1089-98. [pmid: 19132235].
44 Eitz T, Schenk S, Fritzsche D, et al. International normalized ratio self-management lowers the risk of thromboembolic events after prosthetic heart valve replacement. Ann Thorac Surg. 2008;85(3):949-54. [pmid: 18291177].
45 Soliman Hamad MA, van Eekelen E, van Agt T, van Straten AHM. Self-management program improves antiocoagulation control and quality of life: a prospective randomized study. Eur J Cardiothroac Surg. 2009;35:265-9.
46 Heneghan C, Alonso-Coello P, Garcia-Alamino JM, Perera R, Meats E, Glasziou P. Self-monitoring of oral anticoagulation: a systematic review and meta-analysis. Lancet. 2006;367:404-11. [pmid: 16458764].
47 Garcia-Alamino JM, Ward AM, Alonso-Coello P, Perera R, Bankhead C, Fitzmaurice D, et al. Self-monitoring and self-management of oral anticoagulation. Cochrane Database of Systematic Reviews. 2010;(4). Art. No.: CD003839.
48 Stroke Prevention in Atrial Fibrillation (SPAF) Investigators. Bleeding during antithrombotic therapy in patients with atrial fibrillation. Arch Intern Med. 1996;156(4):409-16. [pmid: 8607726].
49 Fihn SD, Callahan CM, Martin DC, et al. The risk for and severity of bleeding complications in elderly patients treated with warfarin. The National Consortium of Anticoagulation Clinics. Ann Intern Med. 1996;124(11):970-9. [pmid: 8624064].
50 White RH, McKittrick T, Takakuwa J, et al. Management and prognosis of life-threatening bleeding during warfarin therapy. National Consortium of Anticoagulation Clinics. Arch Intern Med. 1996;156(11):1197-201. [pmid: 8639014].
51 Beyth RJ, Quinn LM, Landefeld CS. Prospective evaluation of an index for predicting the risk of major bleeding in outpatients treated with warfarin. Am J Med. 1998;105(2):91-9. [pmid: 9727814].
52 McMahan DA, Smith DM, Carey MA, et al. Risk of major hemorrhage for outpatients treated with warfarin. J Gen Intern Med. 1998;13(5):311-6. [pmid: 9613886].
53 Hart RG, Benavente O, Pearce LA. Increased risk of intracranial hemorrhage when aspirin is combined with warfarin: A meta-analysis and hypothesis. Cerebrovasc Dis. 1999;9(4):215-7. [pmid: 10393408].
54 Higashi MK, Veenstra DL, Kondo LM, et al. Association between CYP2C9 genetic variants and anticoagulation-related outcomes during warfarin therapy. JAMA. 2002;287(13):1690-8. [pmid: 11926893].
55 Smith EE, Rosand J, Knudsen KA, et al. Leukoaraiosis is associated with warfarin-related hemorrhage following ischemic stroke. Neurology. 2002;59(2):193-7. [pmid: 12136056].
56 Aspinall SL, DeSanzo BE, Trilli LE, et al. Bleeding Risk Index in an anticoagulation clinic. Assessment by indication and implications for care. J Gen Intern Med. 2005;20(11):1008-13. [pmid: 16307625].
57 Battistella M, Mamdami MM, Juurlink DN, et al. Risk of upper gastrointestinal hemorrhage in warfarin users treated with nonselective NSAIDs or COX-2 inhibitors. Arch Intern Med. 2005;165(2):189-92. [pmid: 15668365].
58 DiMarco JP, Flaker G, Waldo AL, et al. Factors affecting bleeding risk during anticoagulant therapy in patients with atrial fibrillation: observations from the Atrial Fibrillation Follow-up Investigation of Rhythm Management (AFFIRM) study. Am Heart J. 2005;149(4):650-6. [pmid: 15990748].
59 Fang MC, Singer DE, Chang Y, et al. Gender differences in the risk of ischemic stroke and peripheral embolism in atrial fibrillation: the AnTicoagulation and Risk factors In Atrial fibrillation (ATRIA) study. Circulation. 2005;112(12):1687-91. [pmid: 16157766].
60 Gasse C, Hollowell J, Meier CR, et al. Drug interactions and risk of acute bleeding leading to hospitalisation or death in patients with chronic atrial fibrillation treated with warfarin. Thromb Haemost. 2005;94(3):537-43. [pmid: 16268469].
61 Schauer DP, Moomaw CJ, Wess M, et al. Psychosocial risk factors for adverse outcomes in patients with nonvalvular atrial fibrillation receiving warfarin. J Gen Intern Med. 2005;20(12):1114-9. [pmid: 16423100].
62 Douketis JD, Arneklev K, Goldhaber SZ, et al. Comparison of bleeding in patients with nonvalvular atrial fibrillation treated with ximelagatran or warfarin: assessment of incidence, case-fatality rate, time course and sites of bleeding, and risk factors for bleeding. Arch Intern Med. 2006;166(8):853-9. [pmid: 16636210].
63 Flaker GC, Gruber M, Connolly SJ, et al. Risks and benefits of combining aspirin with anticoagulant therapy in patients with atrial fibrillation: an exploratory analysis of stroke prevention using an oral thrombin inhibitor in atrial fibrillation (SPORTIF) trials. Am Heart J. 2006;152(5):967-73. [pmid: 17070169].
64 Fang MC, Go AS, Hylek EM, et al. Age and the risk of warfarin-associated hemorrhage: the anticoagulation and risk factors in atrial fibrillation study. J Am Geriatr Soc. 2006;54(8):1231-6. [pmid: 16913990].
65 Gomberg-Maitland M, Wenger NK, Feyzi J, et al. Anticoagulation in women with non-valvular atrial fibrillation in the stroke prevention using an oral thrombin inhibitor (SPORTIF) trials. Eur Heart J. 2006;27(16):1947-53. [pmid: 16774980].
66 Shireman TI, Mahnken JD, Howard PA, et al. Development of a contemporary bleeding risk model for elderly warfarin recipients. Chest. 2006;130(5):1390-6. [pmid: 17099015].
67 Douketis JD, Melo M, Bell CM, et al. Does statin therapy decrease the risk for bleeding in patients who are receiving warfarin?. Am J Med. 2007;120(4):369 e9-e14.
68 Bousser MG, Bouthier J, Buller HR, et al. Comparison of idraparinux with vitamin K antagonists for prevention of thromboembolism in patients with atrial fibrillation: a randomised, open-label, non-inferiority trial. Lancet. 2008;371(9609):315-21. [pmid: 18294998].
69 Healey JS, Hart RG, Pogue J, et al. Risks and benefits of oral anticoagulation compared with clopidogrel plus aspirin in patients with atrial fibrillation according to stroke risk: the atrial fibrillation clopidogrel trial with irbesartan for prevention of vascular events (ACTIVE-W). Stroke. 2008;39(5):1482-6. [pmid: 18323500].
70 Johnson SG, Rogers K, Delate T, et al. Outcomes associated with combined antiplatelet and anticoagulant therapy. Chest. 2008;133(4):948-54. [pmid: 18198244].
71 Limdi NA, McGwin G, Goldstein JA, et al. Influence of CYP2C9 and VKORC1 1173C/T genotype on the risk of hemorrhagic complications in African-American and European-American patients on warfarin. Clin Pharmacol Ther. 2008;83(2):312-21. [pmid: 17653141].
72 Lindh JD, Holm L, Dahl ML, et al. Incidence and predictors of severe bleeding during warfarin treatment. J Thromb Thrombolysis. 2008;25(2):151-9. [pmid: 17514429].
73 Meckley LM, Wittkowsky AK, Rieder MJ, et al. An analysis of the relative effects of VKORC1 and CYP2C9 variants on anticoagulation related outcomes in warfarin-treated patients. Thromb Haemost. 2008;100(2):229-39. [pmid: 18690342].
74 Metlay JP, Hennessy S, Localio AR, et al. Patient reported receipt of medication instructions for warfarin is associated with reduced risk of serious bleeding events. J Gen Intern Med. 2008;23(10):1589-94. [pmid: 18618191].
75 Limdi NA, Beasley TM, Baird MF, et al. Kidney function influences warfarin responsiveness and hemorrhagic complications. J Am Soc Nephrol. 2009;20(4):912-21. [pmid: 19225037].
76 Poli D, Antonucci NA, Grifoni E, Abbate R, Gensini GF, Prisco D. Bleeding risk during oral anticoagulation in atrial fibrillation patients older than 80 years. J Am Coll Cardiol. 2009;54(11):999-1002. [pmid: 19729116].
77 Lind M, Boman K, Johansson L, et al. Thrombomodulin as a marker for bleeding complications during warfarin treatment. Arch Intern Med. 2009;169(13):1210-5. [pmid: 19597070].
78 Poli D, Antonucci E, Grifoni E, et al. Stroke risk in atrial fibrillation patients on warfarin. Predictive ability of risk stratification schemes for primary and secondary prevention. Thromb Haemost. 2009;101(2):367-72. [pmid: 19190823].
79 Schelleman H, Bilker WB, Brensinger CM, Wan F, Yang YX, Hennessy S. Fibrate/statin initiation in warfarin users and gastrointestinal bleeding risk. Am J Med. 2010;123:151-7. [pmid: 20103024].
80 Gage BF, Yan Y, Milligan PE, et al. Clinical classification schemes for predicting hemorrhage: results from the National Registry of Atrial Fibrillation (NRAF). Am Heart J. 2006;151(3):713-9. [pmid: 16504638].
81 Le Tourneau T, Lim V, Inamo J, et al. Achieved anticoagulation vs prosthesis selection for mitral mechanical valve replacement. A population based outcome study. Chest. 2009;136:1503-13. [pmid: 19482955].
82 Van Leeuwen Y, Rosendaal FR, Cannegieter SC. Prediction of hemorrhagic and thrombotic events in patients with mechanical heart valve prostheses treated with oral anticoagulants. J Thromb Haemost. 2008;6:451-6. [pmid: 18088347].
83 Kuijer PM, Hutten BA, Prins MH, et al. Prediction of the risk of bleeding during anticoagulant treatment for venous thromboembolism. Arch Intern Med. 1999;159(5):457-60. [pmid: 10074953].
84 Gage BF, Waterman AD, Shannon W, et al. Validation of clinical classification schemes for predicting stroke: results from the National Registry of Atrial Fibrillation. JAMA. 2001;285(22):2864-70. [pmid: 11401607].
85 van Walraven C, Jennings A, Oake N, et al. Effect of study setting on anticoagulation control: a systematic review and metaregression. Chest. 2006;129(5):1155-66. [pmid: 16685005].
86 Dolan G, Smith LA, Collins S, Plumb JM. Effect of setting, monitoring intensity and patient experience on anticoagulation control: a systematic review and meta-analysis of the literature. Curr Med Res Opin. 2008;24(5):1459-1472. [pmid: 18402715].
87 Cios DA, Baker WL, Sander SD, Phung OJ, Coleman CI. Evaluating the impact of study-level factors on warfarin control in U.S.-based primary studies: a meta-analysis. Am J Health Syst Pharm. 2009;66(10):916-925. [pmid: 19420310].
88 Christensen TD, Johnsen SP, Hjortdal VE, Hasenkam JM. Self-management of oral anticoagulant therapy: a systematic review and meta-analysis. Int J Cardiol. 2007;118:54-61. [pmid: 16891008].
89 Oake N, Jennings A, Forster AJ, Fergusson D, Doucette S, van Walraven C. Anticoagulation intensity and outcomes among patients prescribed oral anticoagulant therapy: a systematic review and meta-analysis. Can Med Assoc J. 2008;179:235-44. [pmid: 18663203].
90 vanWalraven C, Oake N, Wells PS, Forster AJ. Burden of potentially avoidable anticoagulant-associated hemorrhagic and thromboembolic events in the elderly. Chest. 2007;131:1508-15. [pmid: 17317732].
91 Connolly SJ, Pogue J, Eikelboom J, Flaker G, Commerford P, Franzosi MG. Benefit of oral anticoagulant over antiplatelet therapy in atrial fibrillation depends on the quality of international normalized ratio control achieved by centers and countries as measured by time in therapeutic range. Circulation. 2008;118:2029-37. [pmid: 18955670].
92 Jones M, McEwan P, Morgan CL, Peters JR, Goodfellow J, Currie CJ. Evaluation of the pattern of treatment, level of anticoagulation control, and outcomes of treatment with warfarin in patients with non-valvar atrial fibrillation: A record linkage study in a large British population. Heart. 2005;91:472-77. [pmid: 15772203].
93 Veeger NJ, Piersma-Wichers M, Tijssen JG, Hillege HL, van der Meer J. Individual time within target range in patients treated with Vitamin K antagonists: Main determinant of quality of anticoagulation and predictor of clinical outcome. A retrospective study of 2300 consecutive patients with venous thromboembolism. Br J Haematol. 2005;128:513-9. [pmid: 15686461].
94 White HD, Gruber M, Feyzi J, Kaatz S, Tse HF, Husted S, et al. Comparison of outcomes among patients randomized to warfarin therapy according to anticoagulant control. Arch Intern Med. 2007;167:239-45. [pmid: 17296878].
95 Wittkowsky AK, Sekreta CM, Nutescu EA, Ansell J. Barriers to patient self-testing of prothrombin time: National survey of anticoagulation practitioners. Pharmacotherapy. 2005;25:265-9. [pmid: 15767240].
96 Ansell J, Jacobson A, Levy J, et al. Guidelines for implementation of patient self-testing and patient self-management of oral anticoagulation. International consensus guidelines prepared by International Self-Monitoring Association for Oral Anticoagulation. Int J Cardiol. 2005;99(1):37-45. [pmid: 15721497].
97 Connolly SJ, Ezekowitz MD, Yusuf S, et al. Dabigatran versus warfarin in patients with atrial fibrillation. N Engl J Med. 2009;361(12):1139-51. [pmid: 19717844].
98 Schulman S, Kearon C, Kakkar AK, et al. Dabigatran versus Warfarin in the Treatment of Acute Venous Thromboembolism. N Engl J Med. 2009;361(24):2342-52. [pmid: 19966341].