# DISCUSSION AND RECOMMENDATIONS

## KEY QUESTION 1 For management of long-term outpatient anticoagulation in adults, are specialized anticoagulation clinics (ACC) more effective and safer than care in non-specialized clinics (e.g., primary care clinics, physician offices)?

### Major Clinical Outcomes

The literature available to address this question is limited. We were able to identify 11 studies, of which only 3 were RCTs.6,7,8 Except for one study,14 major clinical outcomes occurred more frequently in the control than the intervention group (Table 3). However, pooled results from the 3 RCTS showed no significant differences between ACC and UC for deaths, thromboembolic events, or major bleeding. Pooling of the observational studies' results was not possible due to heterogeneity among studies in reported outcome metrics.

### Time in Therapeutic Range

All 9 studies that reported this metric (or the related metric, % INRs within therapeutic range) found that subjects receiving care in an ACC spent more time within the therapeutic range than those who received usual care.6-8,10-14,16 In 4 studies the difference was statistically significant.7,10,12,14 In the RCTs, the pooled weighted means were only slightly higher for ACC than UC (59.9% v.56.3%). In the observational studies, there was a larger spread with ACC patients spending 63.5% of the time in therapeutic range compared to 53.5% for subjects in usual care.

### Patient Satisfaction

Measured in 2 of the RCTs, patient satisfaction was found to be significantly higher in patients randomized to the ACC intervention than to UC.6,7

### Other Reviews

The 2008 ACCP guidelines on Pharmacology and Management of the Vitamin K Antagonists1 included a narrative review of 9 uncontrolled studies, 3 cohort studies, and 2 RCTs. The authors concluded that “although the literature … is not as robust as one would like, and there is great heterogeneity between studies, the results are almost always consistent, indicating that care provided by an anticoagulation management service results in better outcomes or more stable therapy than UC” (p 184s1). Similarly a systematic review and meta-regression published in 2006^85^ found that care provided in community settings resulted in significantly worse anticoagulation control (as measured by TTR) than that provided within ACCs (or within clinical trials). This review included studies of any design as long as the report included original data measuring serial INRs in at least one patient group. A third review and meta-analysis of 36 studies of patients with atrial fibrillation found that significantly more time was spent within the therapeutic range when patients were cared for in organized settings (i.e., ACCs) as compared with usual care.86 Finally, a very recent meta-analysis investigated the effect of study-level factors (e.g., study design, year of publication, INR interpolation method) on time in therapeutic range and reported that patients managed in ACCs spent significantly more time within the therapeutic range than those managed in usual care.87 None of these reviews evaluated clinical outcomes.

## KEY QUESTION 1A Which components of a specialized anticoagulation clinic are associated with effectiveness/ safety?

None of the included studies reported the association between specific elements of ACC and outcomes. Some possible processes of care that might have accounted for observed differences in outcomes in these studies included use of both face-to face and telephone interactions with patients;13 use of a computerized patient monitoring system that identified patients who were delinquent in returning for timely INR determinations;12 the specialized expertise of the ACC staff;12 more consistency in ACCs in obtaining regular INRs;11 and frequency of face-to-face consultations, methods of dosage adjustment, and provision of written dosage instructions.16

## CONCLUSION AND RECOMMENDATIONS FOR KQ1

The evidence suggests that care provided within ACCs may lead to better quality anticoagulation control as measured by time in therapeutic range (a surrogate outcome that has been correlated with clinical events),50 but there is insufficient evidence to conclude that ACC care leads to fewer deaths, thromboembolic events, or major bleeding events than care provided in usual care settings such as primary care clinics. Patients reported that they liked the convenience and enhanced service provided by ACCs. There is insufficient evidence for the VA to actively promote the implementation of ACCs. Other organizations have suggested greater benefits with ACCs; future research should include cost and resource utilization outcomes along with clinical outcomes and patient satisfaction measures. Future research should also address whether the benefits from ACC are restricted to the initiation of anticoagulation (a high risk period) or also continue through the maintenance phase.

## KEY QUESTION 2 Is Patient Self Testing (PST), either alone or in combination with Patient Self Management (PSM), more effective and safer than standard care delivered in either ACCs or non-specialized clinics?

This analysis of 22 randomized, controlled trials (RCTs) indicates that for selected patients, oral anticoagulation therapy delivered through a PST/PSM model results in superior patient outcomes compared with oral anticoagulation therapy delivered through usual clinic based models. Patients randomized to PST/PSM, had a significant 26% lower risk of death and a significant 42% reduction in major thromboembolism without any increased risk of major bleeding events. We included between 4-12 more trials and 3500-5000 more patients than other meta-analyses2,46,47,88 and to our knowledge we are the first to include the largest trial to date, The Home INR Study, a VA cooperative studies trial17.

The mechanism by which PST/PSM leads to a reduction in thromboembolic events is thought to involve the higher proportion of time spent within the therapeutic range that is achieved with more frequent monitoring and dosage adjustments. This assumption has been predicated on observational data suggesting that the incidence of bleeding and thromboembolism is correlated with the quality of anticoagulation control (i.e., time in therapeutic range or % INR values within therapeutic range).89-93 The recent VA trial also found a modest but statistically significant higher percent time within therapeutic range for patients randomized to PST than to usual care (absolute difference 3.8 percentage points).17 Our study did not confirm this association, possibly because our analysis, which included the largest number of trials to-date, was limited to RCTs whereas other reports were either from single RCTs,17,91,94 reviews that included both RCTS and observational studies,89 database analyses90,92 or retrospective cohort studies.93

It is important to note that these trials enrolled highly selected populations. Subjects had to have the desire and confidence as well as the manual dexterity, visual acuity, and mental faculties to use the testing device and either relay those values to their clinic (PST) or perform dose adjustment on their own (PSM). In most of the trials, 50% or fewer patients met preliminary eligibility criteria, successfully completed the training, and agreed to be randomized. Some of the reasons cited for patient unwillingness to participate or continue with the PST/PSM included patient-perceived physical limitations, lack of confidence in their ability to follow the protocol, difficulty performing measurements, and preference for an alternative method.25,46 However, among the randomized patients, the percentage who continued with the intervention throughout the study was relatively high (64-98%) and patients in the PST/PSM group generally reported higher satisfaction and quality of life than those in usual care.

Several limitations of this analysis should be acknowledged. First, the methodological quality of the included trials was variable; only 5 trials met all of our quality indicators. Second, it is unclear whether the apparent benefits of PST/PSM result from the PST/PSM or simply from the more intense education that these patients receive. Third, the current data do not address the question of whether PST/PSM is safe during the high-risk initiation phase or should only be implemented during the maintenance phase. However, it is reassuring to note that in the VA trial there was no outcome difference between the group who had been randomized within 3 months of starting anticoagulation and the group that had been anticoagulated for more than 3 months.17 Finally, the data on quality of life and patient satisfaction is difficult to interpret due to the wide range and variable quality of the outcome measures used.

Whether the results of this review can be applied to US health care systems is unclear. Only 2 of the 22 reviewed trials were conducted in the US17,18 and both investigated PST not PSM. Furthermore, one of these, the VA trial, did not show a significant benefit among patients randomized to PST compared to those randomized to a high quality ACC. The generalizability of results from non-US trials to US health care settings is problematic since half of these trials used vitamin K antagonists not widely used in the US and several of these have markedly different half lives from warfarin.1 Also, since PST/PSM is a complex multi-component intervention, it is important to have evidence of effectiveness in typical US healthcare settings. Finally, although we did not examine costs, survey data suggest that costs are likely to be a barrier to implementation.95 Several cost analyses have concluded that implementing PST/PSM may not be cost-effective due to the high cost of the portable monitoring devices and supplies and of patient training.2,96

## CONCLUSION AND RECOMMENDATIONS FOR KQ2

This analysis indicates that compared to usual clinic care, patient self testing with or without self management is associated with significantly fewer deaths and thromboembolic events without any increase in bleeding complications, for a select group of motivated patients requiring long term anticoagulation with Vitamin K antagonists. It should be noted, however, that while the strength of evidence was moderate for the thromboembolism and bleeding, it was low for mortality. Whether this care model is cost-effective and can be implemented successfully in typical US health care settings requires further study.

## KEY QUESTION 3 What are the risk factors for serious bleeding in patients on chronic anticoagulant therapy?

### Summary

Many factors have been shown to predict an increased risk of serious bleeding; however, there is no standard set of variables that is commonly reported such that coming up with a comprehensive list of independent risk factors is difficult and involves piecing together results from a very heterogeneous group of studies. Factors that seemed most consistently associated with serious bleeding included: very old age, the first months following warfarin initiation, other medication use (particularly aspirin use), comorbid conditions (such as history of GI bleeding events or diabetes), primary indication for taking warfarin was a valve condition, and genetic factors (ex. variation in the CYP2C gene). There have also been a number of studies of indices that pool together several of the before mentioned risk factors and shown that patients can to some extent be categorized into low, intermediate, and higher risk for serious bleeding events. Those identified as low risk typically have a several-fold lower risk of bleeding events compared to those identified as high risk. The amount of separation depended in part on the population. For example a population where most of the patients are generally at a low risk of major bleeding will tend to show little separation, because there is not much of a range in risk.

### Limitations

Publication bias and the inability to pool results across studies due the heterogeneity of the study designs, analytical methods, and risk factors assessed limit the certainty that can be assigned to the results presented in this section. Publication bias is a concern when looking at lists of predictors of outcomes from observational studies. It is not uncommon for studies to evaluate associations for many more factors than they report results, creating a situation where, positive associations with bleeding may be more often reported than null associations. This may make some factors look artificially more strongly associated than they might be expected to be in real-world circumstances. For this reason, it is important to confirm more novel associations in large prospective studies. The range of uncertainty around the magnitude of effect for any of these risk factors is also necessarily large, since the heterogeneity of the studies precludes anything but a narrative review of the findings.

## CONCLUSION AND RECOMMENDATIONS FOR KQ3

Several factors have been shown to consistently predict an increased risk of bleeding and, when pooled together, a subset of these risk factors has been shown to stratify groups of patients into lower and higher risk groups. Either alone or in combination, these risk factors can likely be used to help clinicians and patients have a dialog about the risks of warfarin therapy. Currently, there is not adequate evidence to suggest that any of the bleeding risk indices are meaningfully superior to the other indices. The HEMORR_2_HAGES index seems to be the most comprehensive list of potential factors, while the OBRI index has been the most frequently tested model and is more parsimonious. While neither of these is clearly superior, it does seem that there is growing support for the development of more formal methods of risk assessment beyond that of simple clinical intuition or judgment, and the current risk indices provide a means to begin to be develop useful clinical support tools that can be tweaked as new risk factors are identified.

Future studies might better define the utility of these risk indices by randomizing patients to different bleed risk management strategies possibly incorporating different combinations of risk factors or bleeding risk indices to assess the potential benefits and harms of different anticoagulation strategies.

## FUTURE DIRECTIONS

The questions addressed in this review may become moot within the next several years. Very recent randomized controlled trials suggest that direct thrombin inhibitors, drugs currently being evaluated for the United States market, and which do not require intensive monitoring, may be as safe and efficacious as vitamin K antagonists. Specifically, in large randomized trials, dabigatran has been shown to be equivalent to warfarin for the prevention of thromboembolic events in patients with chronic atrial fibrillation97 and deep vein thrombosis.98 The long term safety of these new agents is not yet established. In one trial,97 myocardial infarction was more common among patients randomized to dabigatran than to warfarin, although this association was only marginally significant. Furthermore, liver function abnormalities were observed with use of an older direct thrombin inhibitor, ximelagatran,98 although to date this has not been observed with dabigatran. Final FDA approval of these products may significantly alter the standard for anticoagulation therapy and subsequent monitoring.