# EVIDENCE TABLES

Appendix B, Table 1 Randomized Controlled Trials for Anticoagulation Clinic versus Usual Care (KQ1)

Study Publication Year Country of Origin Funding source | Indication for anticoagulation Entrance criteria Duration of follow-up Mean age % Male Inception Cohort/Time on OAC prior to enrollment | Intervention Group (n) Control Group (n) Total sample size (N) | Outcomes evaluated^*^ | Study quality
Matchar, et al.8 2002 USA Agency for Healthcare Research and Quality, DuPont Pharmaceuticals Company | Atrial fibrillation Age ≥ 65, atrial fibrillation, enrolled in 1 of 6 managed care organizations Mean Age: 76+ 7 % Male: 49 A follow-up period of the 9 months immediately after the anticoagulation service had attained the minimum enrollment Inception: unclear | Intervention Cluster: referred to ACC: 173, not referred to ACC: 190 Control Cluster: 317 N=680 2 Practice clusters within each site were randomized to either access or no access to an ACC. The intervention clusters did not HAVE to refer pts to the ACC. | iii VTE; iv Bleeding; vii Time in Therapeutic Range | Allocation concealment: NA Blinding: NR Intention-to-treat: NR Dropouts reported: yes
Wilson, et al.6 2003 Canada Queen Elizabeth II Health Sciences Centre Research Foundation (Halifax, NS), Physicians' Services Incorporated Foundation (Ottawa, ON), London Health Sciences Centre Internal research Fund (London, ON) | Mixed indications All patients expected to be on warfarin ≥ 3mo Mean Age: 61+ 15 years % Male: 58 Follow-Up: 3 months Inception (< 1 month): 81% | Intervention: ACC: 112 Control: family physician: 109 N = 221 | i All cause mortality; ii Event related mortality; iii VTE; iv Bleeding; v Patient Satisfaction; vii Time in Therapeutic Range | Allocation concealment: yes Blinding: clinical event adjudication committee blinded Intention-to-treat: yes Dropouts reported: yes
Chan, et al.7 2006 China Health Care and Promotion Fund (Hong Kong) | Mixed indications All patients, age ≥ 18, requiring ≥ 3mo of warfarin therapy Mean Age: 59 + 14 years % Male: 45 Follow-Up: max 2 years, average length cannot be determined Inception cohort: see page 602 | Intervention: pharmacist-managed ACC: 69 Control: hematologist-managed ACC: 69 N = 138 | i All cause mortality; iii VTE; iv Bleeding; v Patient Satisfaction; vii Time in Therapeutic Range; xi Hospitalization; xii Outpatient Utilization; xiii ER Utilization | Allocation concealment: unclear Blinding: NR Intention-to-treat: no Dropouts reported: yes

* OUTCOMES

i. All cause mortality
ii. Event related mortality
iii. VTE (venous thromboembolic events)
iv. Bleeding
v. Patient Satisfaction
vi. Quality of Life
vii. Time in Therapeutic Range
viii. % of INRs in Therapeutic Range
ix. INR Variability
x. # of Total INR Values
xi. Hospitalization
xii. Outpatient Utilization
xiii. ER Utilization
xiv. Outpatient Laboratory Utilization
xv. Long-term Care Admission (after related event)

Appendix B, Table 2 Observational Studies for Anticoagulation Clinic versus Usual Care (KQ1)

Study Publication Year Country of Origin Funding Source | Study design Indication for anticoagulation Entrance criteria Duration of follow-up Mean age % Male % Inception/time on OAC prior to enrollment | Intervention Group (n) Control Group (n) Total sample size (N) | Outcomes evaluated^*^
Lee, et al.9 1996 USA | Prospective Cohort Mixed indications All patients discharged from hospital requiring long term warfarin. Follow-Up: 3 mos Mean Age: 56.9 % Male: 57 Inception: NR | Intervention: Hospital discharges requiring long term anticoagulation referred to anticoagulation clinic. The ACC was led by a pharmacist and included patient education via manuals, videos and compliance aids. (68) Control: Random sample of hospital discharges requiring long term warfarin but not referred to anticoagulation clinic (68) N = 136 | xi Hospitalization
Chiquette, et al.10 1998 USA | Retrospective Cohort Mixed Indications All patients, requiring ≥3mo of warfarin therapy, with at least one outpatient visit Follow-Up: NR Mean Age: NR (90% < 65) % Male: 53 Inception: 100% | Intervention: ACC which was led by a pharmacist and included intensive patient education; no dosing algorithm (183) Control: Usual medical care (145) N = 328 | iii VTE; iv Bleeding; vii Time in Therapeutic Range; viii % of INRs in Therapeutic Range; xi Hospitalization; xiii ER Utilization
Chamberlain, et al.11 2001 USA Southwest Washington Medical Center | Retrospective Cohort Mixed indications All anticoagulation patients during study period included Follow-Up: NR Mean Age: 63 + 15 % Male: 42 Inception: No/NR | Intervention: Anticoagulation patients during the period 11/1/1996 to 10/31/1997 followed in a pharmacist-run anticoagulation clinic which included POC testing (41) Control: Anticoagulation patients during the period 11/1/1996 to 10/31/1997 followed in a family medicine clinic that did not perform POC testing (75) N = 116 | iii VTE; viii % of INRs in Therapeutic Range; xi Hospitalization; xiii ER Utilization
Witt, et al.12 2005 USA | Retrospective Cohort Mixed indications ≥ 18yo, on warfarin, ≥2 INR values during 6 mo evaluation period Follow-Up: 6 months Mean Age: 67.8 % Male: 53 Inception: NR | Intervention: Anticoagulation therapy managed by a centralized, telephonic clinical pharmacy anticoagulation service manned by pharmacists available 24/7; patient education provided (3323) Control: Anticoagulation therapy managed per usual personal physician. (3322) N = 6645 | i All cause mortality; ii Event related mortality; iii VTE; iv Bleeding; vii Time in Therapeutic Range
Du, et al. 14 2005 China | Prospective cohort Atrial fibrillation NVAF on anticoagulation Follow-Up: NR Mean Age: 61.8 % Male: 59 Inception: NR | Intervention: referred to anticoagulation clinic (details not provided) (66) Control: followed by usual care which consists of follow-up by cardiology outpatient clinic (138) N = 204 | iii VTE; iv Bleeding; viii % of INRs in Therapeutic Range
Ansell, et al.16 2007 USA, Sweden, Italy, Spain, France AstraZeneca Pharmaceuticals | Retrospective Cohort Atrial fibrillation Cross-sectional cohort with chronic NVAF, age >18, minimum 60 days of AC Follow-Up: 12 months Mean Age: NR % Male: NR Inception: NR | Intervention: Patients of anticoagulation clinics using local protocols were followed in Italy and Spain. ACC management was defined as care provided in a systematic way by personnel focusing specifically on AC management (395) Control: Patients of routine medical care using local protocols were followed in the US, Canada and France (1116) N = 1511 | vii Time in Therapeutic Range; viii % of INRs in Therapeutic Range
Wallvik, et al.15 2007 Sweden Joint Committee of Northern Sweden Health Care Region and Foundation of Medical Research in Skelleftea | Prospective Cohort Mixed indications All patients treated with warfarin in two regions of northern Sweden. Follow-Up: 1.8 years (mean), 4 yrs max Mean Age: 69 % Male: 58 Inception cohort: NR | Intervention: Anticoagulation clinic, no details provided (1537) Control: Primary healthcare centre (1194) N = 2731 | iv Bleeding
Nichol, et al.13 2008 USA AstraZeneca Pharmaceuticals | Retrospective Cohort Atrial Fibrillation NVAF on anticoagulation Follow-Up: 12 mos Mean Age: NR % Male: 55 Inception: No | Intervention: ACC run by an RN mostly by phone, supervised by a cardiologist; intensive pt education on first visit. (351) Control: Usual care by internists, GPs or cardiologists. (756) N = 1107 | iii VTE; iv Bleeding; vii Time in Therapeutic Range

* OUTCOMES

i. All cause mortality
ii. Event related mortality
iii. VTE (venous thromboembolic events)
iv. Bleeding
v. Patient Satisfaction
vi. Quality of Life
vii. Time in Therapeutic Range
viii. % of INRs in Therapeutic Range
ix. INR Variability
x. # of Total INR Values
xi. Hospitalization
xii. Outpatient Utilization
xiii. ER Utilization
xiv. Outpatient Laboratory Utilization
xv. Long-term Care Admission (after related event)

Appendix B, Table 3 Overview of individual short-term (<12 months) randomized, controlled trials investigating PST/PSM (KQ2)

Study Publication year Country of origin Funding source | Indications for anticoagulation Entrance criteria Duration of follow-up Mean age % Male Length of time on OAC prior to enrollment | Intervention group (n) Control group (n) Total sample size (N) Type of vitamin K antagonist | Outcomes evaluated^*^ | Study quality
Sawicki et al. 1999^20^ Germany Industry | Mixed Patients with a disease or condition requiring lifelong OAC 6 months 55±12 years 70% male 2.1±4.8 years (mean) Not clear (pts were not previously treated in THESE clinics) | Intervention: PSM (n=90) Control: PC clinic (n=89) N=179 Phenprocoumon | iii Thromboembolic events; iv Major bleeding events; v Patient satisfaction/quality of life; vii INR variability | Allocation concealment: adequate Blinding: lab techs doing the INRs were blinded Intention-to-treat: yes Dropouts reported: yes
Beyth et al. 2000^18^ USA NIH, VA HSR&D, American Federation for Aging Research | Mixed Patients aged ≥65 years, residing in Cuyahoga County, OH, starting on OAC with treatment planned for ≥10 days 6 months 75 ± 6.8 years (range 65-94) 43% male 0 years (inception cohort) | Intervention: PST (n=163) Control: PC clinic (n=162) N=325 Warfarin | i All-cause mortality; iii Thromboembolic events; iv Major bleeding events; viI % time within therapeutic range | Allocation concealment: unclear Blinding: two author-reviewers who were blinded to group assignment adjudicated bleeding events Intention-to-treat: yes Dropouts reported: yes
Cromheecke et al. 2000^21^ Crossover trial The Netherlands Not reported | Mixed Self-supporting patients receiving long-term OAC 6 months (each pt followed 3 mos in each treatment) 42 ± 16 years (range 21-71) 59% male 3.9±2.2 years (mean) (not inception) | Intervention: PSM (n=50) Control: AC clinic (n=50) (Total N=50) Phenprocoumon and acenocoumarol | iii Thromboembolic events; iv Major bleeding events; v Patient satisfaction/quality of life; vi % time within therapeutic range; vii % INR values within therapeutic range | Allocation concealment: adequate Blinding: NR Intention-to-treat: unclear Dropouts reported: yes
Fitzmaurice et al. 2002^22^ United Kingdom Industry | Mixed Patients aged ≥18 years, on long-term OAC for ≥6 months previously, with good vision and manual dexterity, and with INR within 0.5 of target value at least 60% of the time over the prior 12 months 6 months 66 years 76% male Not reported (not inception) | Intervention: PSM (n=30) Control: AC clinic (n=26) N=56 Warfarin | iv Major bleeding events; v Patient satisfaction/quality of life; vi % time within therapeutic range; vii % INR values within therapeutic range | Allocation concealment: unclear Blinding: no Intention-to-treat: no Dropouts reported: yes
Gadisseur et al. 2003^23^ & Gadisseur et al. 2004^24^ The Netherlands Industry | Mixed Patients aged 18-75, requiring long-term OAC, with ≥3 months experience on OAC 24.4 weeks (mean) 59 years 71% male Not reported (not inception) | Intervention (1): PST (n=52) Intervention (2): PSM (n=47) Control (1): AC clinic patients aware of the study and receiving education about OAC (n=60) Control (2): AC clinic patients not aware of the study (n=161) N=320 Phenprocoumon and acenocoumarol | iii Thromboembolic events; iv Major bleeding events; v Patient satisfaction/quality of life; vi % time within therapeutic range; vii % INR values within therapeutic range | Allocation concealment: adequate Blinding: physicians evaluating and correcting the proposed dosing schedules for group A and group B Intention-to-treat: yes Dropouts reported: yes
Khan et al. 2004^25^ United Kingdom BUPA Foundation | Atrial Fibrillation Patients aged ≥65 years without dementia, on warfarin for ≥12 months, with a target INR of 2-3, with an INR standard deviation of ≥ 0.5 over prior 6 months 6 months Median age 73 yrs (range: 65-93) 58% male Not reported (not inception) | Intervention: PST (n=44) Control (1): ACC patients aware of the study and receiving education about OAC (n=41) Control (2): ACC patients not aware of the study (n=40) N=125 Warfarin | iii Thromboembolic events; iv Major bleeding events; v Patient satisfaction/quality of life; vi % time within therapeutic range | Allocation concealment: unclear Blinding: NR Intention-to-treat: no Dropouts reported: yes
Sunderji et al. 2004^19^ Canada Industry and others | Mixed Patients age ≥ 18 years on warfarin for ≥ 1 month with target INR range 2-3 or 2.5-3.5, without mental incompetence or known hypercoagulable disorders 8 months 60 years 71% male 53.5% with ≥ 6 months OAC | Intervention: PSM (n=70) Control: PC clinic (n=70) N=140 Warfarin | iii Thromboembolic events; iv Major bleeding events; v Pt Satisfaction; vi % time within therapeutic range; vii % INR values within therapeutic range | Allocation concealment: adequate Blinding: no Intention-to-treat: yes Dropouts reported: yes
Gardiner et al. 2005^26^ United Kingdom Industry | Mixed Patients aged ≥18 years attending the anticoagulation clinic at University College London Hospital, on OAC for ≥8 months, with previous record of good compliance 6 months 58 years (range 26-83) (unclear if mean or median) 63% male Not reported (not inception) | Intervention: PST (n=44) Control: AC clinic (40) N=84 Warfarin | iv Major bleeding events; v Pt Satisfaction; vi % time within therapeutic range | Allocation concealment: unclear Blinding: no Intention-to-treat: unclear Dropouts reported: yes
Voller et al. 2005^27^ Germany Industry | Atrial fibrillation Patients on OAC for atrial fibrillation, without alcoholism or other addictions 39±6 mos 64 ± 9.3years 66% male Not reported | Intervention: PSM (n=101) Control: PC clinic (n=101) N=202 Not reported | iii Thromboembolic events; iv Major bleeding events; vi % time within therapeutic range (# of days); vii % INR values within therapeutic range | Allocation concealment: unclear Blinding: no Intention-to-treat: unclear Dropouts reported: unclear
Christensen et al. 2006^28^ & Christensen et al. 2007^29^ Denmark Danish Heart Foundation | Mixed Patients aged ≥18 years on OAC for ≥8 months 182 days (mean) 49 ± 13.7 years 67% male 5.5±4.3 years (mean) Not reported (not inception) | Intervention: PSM (n=50) Control: PC/AC clinic (n=50) N=100 Warfarin and phenprocoumon | i All-cause mortality; iii Thromboembolic events; iv Major bleeding events; vi % time within therapeutic range; viii INR variability | Allocation concealment: no Blinding: no Intention-to-treat: no Dropouts reported: yes
Gardiner et al. 2006^30^ United Kingdom Industry | Mixed Patients aged ≥18 years on long-term OAC for ≥8 months, without history of poor compliance, intellectual impairment, or known drug or alcohol dependency 6 months 60 years (22-88) 61% male Not reported (not inception) | Intervention: PSM (n=55) Control: PST (n=49) N=104 Warfarin | vi % time within therapeutic range | Allocation concealment: unclear Blinding: no Intention-to-treat: unclear Dropouts reported: yes
Dauphin et al. 2008^31^ France Industry | MHV replacement Patients undergoing mechanical valve replacement at Clermont-Ferrand University Hospital 47 ± 12 weeks (mean) 57 ± 9.7 years 67% male Not reported (recruited when undergoing valve replacement) | Intervention: PST (n=33) Control: AC clinic (n=34) N=67 Fluindione and acenocoumarol | i All-cause mortality; iii Thromboembolic events; iv Major bleeding events; vi % time within therapeutic range; vii % INR values within therapeutic range; viii INR variability | Allocation concealment: unclear Blinding: no Intention-to-treat: unclear Dropouts reported: yes
Ryan et al. 2009^32^ Crossover trial Ireland Industry and Health Research Board, Ireland | Mixed Patients on OAC for ≥2 months who had internet access. 6 months 58.7 ± 14.3 years 62% male Not reported (not inception) | Intervention: PSM (n=132 completed both arms, 72 initially) Control: AC clinic (n=132, 60 initially) N=162 Warfarin | iii Thromboembolic events; iv Major bleeding events; vi % time within therapeutic range | Allocation concealment: adequate (pharmacy-controlled) Blinding: no Intention-to-treat: no Dropouts reported: yes

* OUTCOMES

i. All cause mortality
ii. Event related mortality
iii. VTE (venous thromboembolic events)
iv. Bleeding
v. Patient Satisfaction
vi. Quality of Life
vii. Time in Therapeutic Range
viii. % of INRs in Therapeutic Range
ix. INR Variability
x. # of Total INR Values
xi. Hospitalization
xii. Outpatient Utilization
xiii. ER Utilization

Appendix B, Table 4 Overview of individual long-term (≥12 months) randomized, controlled trials investigating PST/PSM (KQ2)

Study Publication year Country of origin Funding source | Indications for anticoagulation Entrance criteria Duration of follow-up Mean age % Male Inception cohort/ time on OAC prior to enrollment | Intervention (n) Control (n) Total sample size (N) Type of vitamin K antagonist | Outcomes evaluated^*^ | Study quality
Horstkotte et al. 1998^34^, 1996^33^ (abstract) Germany Not reported | MHV replacement Entrance criteria not reported 17.7 months (mean) Not reported Not reported Not reported | Intervention: PSM (n=75) (dosing unclear) Control: PC clinic (n=75) N=150 Not reported | iii Thromboembolic events; iv Major bleeding events; vii % INR measurements within therapeutic range | Allocation concealment: unclear Blinding: NR Intention-to-treat: unclear Dropouts reported: unclear
Koertke et al. 2001 (one in German in Z Kardiol35 and one in Ann Thor Surg36) & Koertke et al. 2007^37^ Germany Not reported | MHV replacement Patients undergoing MHV replacement from 2/1994-10/1997 at a German institution Initial f/u: 38 mos Long-term f/u: 9.3 +/- 2.8 years 63 years 66% male Inception Cohort | Intervention: PSM (n=579 in 2001; 488 in 2007) Control: PC clinic (n=576 in 2001; 442 in 2007) N (2001)=1155 N (2007)=930 Phenprocoumon | i All-cause mortality(2007); ii Event-related mortality (2007); iii Thromboembolic events (2001); iv Major bleeding events (2001); vii % INR values within therapeutic range (2001) | Allocation concealment: unclear Blinding: NR Intention-to-treat: unclear Dropouts reported: yes
Sidhu et al. 2001^38^ United Kingdom Industry | MHV replacement Patients who had undergone MHV replacement by the author and were ≤ 85 yo without visual difficulties 24 months 61 years (range: 26-85) 46% male Not reported | Intervention: PSM (n=51) Control: PC or AC clinic (n=49) N=100 Warfarin | i All-cause mortality; ii Event-related mortality; iii Thromboembolic events; iv Major bleeding events; vii % time within therapeutic range | Allocation concealment: unclear Blinding: NR Intention-to-treat: unclear Dropouts reported: yes
Fitzmaurice et al. 2005^39^ & Jowett et al. 2006^40^ United Kingdom United Kingdom Medical Research Council | Mixed Patients aged ≥18 years on warfarin for ≥6 months with treatment indicated for ≥12 months, with a target INR of 2.5-3.5 12 months 65 years 65% male Not reported (not inception) | Intervention: PSM (n=337) Control: AC clinic (n=280) N=617 Warfarin | - All-cause mortality; - Event-related mortality; - Thromboembolic events; - Major bleeding events; - Patient satisfaction/quality of life; - % time within therapeutic range | Allocation concealment: adequate Blinding: no Intention-to-treat: yes Dropouts reported: yes
Menendez-Jandula et al. 2005^41^ Spain Industry | Mixed Patients aged ≥18 years on long-term OAC for ≥3 months, without severe physical or mental illness 12 months (median f/u) 65 years 53% male 5.1 years (median, IQR 2.0-12.0) % inception NR | Intervention: PSM (n=368) Control: AC clinic (n=369) N=737 acenocoumarol | i All-cause mortality; iii Thromboembolic events; iv Major bleeding events; vi % time within therapeutic range; vii % INR values within therapeutic range; viii INR variability (INR distance, table 2) | Allocation concealment: adequate Blinding: complications diagnosed and evaluated by a third physician not involved in the trial and unaware of patients' study group Intention-to-treat: yes Dropouts reported: yes
Siebenhofer et al. 2007^42^ & Siebenhofer et al. 2008^43^ Austria Industry | Mixed Patients aged ≥60 years, on long-term OAC, without severe cognitive problems or terminal illness 2.9 ± 1.2 years (mean) 69 ± 6.3 years 58% male 5.7 ±7.1 years (mean) Not inception | Intervention: PSM (n=99) Control: AC/PC clinic (n=96) N=195 Phenprocoumon and acenocoumarol | i All-cause mortality; ii Event-related mortality (see table 4 p. 1096); iii Thromboembolic events; iv Major bleeding events; vi % time within therapeutic range; vii % INR values within therapeutic range; viii INR variability | Allocation concealment: adequate Blinding: complications evaluated by two independent physicians not involved in the trial and unaware of patients' study group. Intention-to-treat: yes Dropouts reported: yes
Eitz et al. 2008^44^ Germany Not reported | MHV replacement Patients undergoing MHV replacement in a German hospital 2 years 58.7 years 69% male Not reported (randomized at time of valve replacement) | Intervention: PSM (n=470) Control: PC clinic (n=295) (crossovers were allowed) N=765 Warfarin | iii Thromboembolic events; iv Major bleeding events; vii % INR values within therapeutic range; viii INR variability | Allocation concealment: unclear Blinding: NR Intention-to-treat: no Dropouts reported: no
Soliman Hamad 2009^45^ The Netherlands Not reported | MHV replacement Patients undergoing MHV replacement in a Dutch hospital with knowledge of computers and the internet. 12 months 56 years Not reported Inception cohort (randomized at time of valve replacement) | Intervention: PSM (n=29) Control: AC clinic (n=29) N=62 Not reported | i All-cause mortality; iii Thromboembolic events; iv Major bleeding events; v Pt Satisfaction /quality of life; vi % time within therapeutic range | Allocation concealment: unclear Blinding: NR Intention-to-treat: no Dropouts reported: yes
Matchar (THINRS) 2010^17^ USA VA | Mixed Patients with MHV replacement or atrial fibrillation and competent in device use 2 to 4.75 years 67 ± 9 years 98% male Not an inception cohort (mean time on OAT prior to enrollment not reported) | Intervention: PST (n=1,465) Control: AC clinic (n=1,457) N=2922 Warfarin | i All-cause mortality; iii Thromboembolic events; iv Major bleeding events; v Pt Satisfaction /quality of life; vi % time within therapeutic range | Allocation concealment: adequate Blinding: major outcomes assessed by independent adjudicators Intention-to-treat: yes Dropouts reported: yes

* OUTCOMES

i. All cause mortality
ii. Event related mortality
iii. VTE (venous thromboembolic events)
iv. Bleeding
v. Patient Satisfaction
vi. Quality of Life
vii. Time in Therapeutic Range
viii. % of INRs in Therapeutic Range
ix. INR Variability
x. # of Total INR Values
xi. Hospitalization
xii. Outpatient Utilization
xiii. ER Utilization

Appendix B, Table 5 Overview of Individual Studies – Risk Factors for Serious Bleeding (KQ3)

Study Country of origin Funding source | Study design Indications for anticoagulation Entrance criteria Duration of follow-up (years) | N (cases) Mean age % Male | Definition of Serious Bleeding | Serious Bleeding Outcomes by Risk Factors
Aspinall 2005^56^ United States Public | Retrospective cohort study using Administrative Datasets Patients attending a VA anticoagulation clinic between 2001 and 2002 Follow-up Administrative Data from January 1, 2001 to December 31, 2002 | N(cases): 1,269 (42) Mean age: 67.9 (SD=11.4) 92% Male | Patient was hemo-dynamically unstable, required a transfusion, had an intracranial hemorrhage, or died. | [underlined: Risk Index] (Bleeding Risk Index) * Low: 0.8% /PYr (95% CI; 0-4.2) Med: 2.5%/PYr (95%CI;1.6-3.7) High: 10.6% /PYr (95% CI; 6.4-16.6) [underlined: Warfarin Duration] (p=.08)^*^ New User (n/N): 2.2% (11/502) Prior User (n/N): 4.0% (31/767)
Battistella 2005^57^ Canada Public | Nested case-control study using Administrative Datasets Cohort of continuous warfarin users from April 1, 2000, to March 31, 2001 Follow-up 1 year | N(cases): 1,798 (361) Mean age: 77 (SD=6.8) 49% Male | Patient was admitted to the hospital with any diagnosis of upper GI hemorrhage | [underlined: Other Med Use]^***^ NSAID: OR=1.9 (95%CI;1.4-3.7) Cox-2 Inhibitors Celecoxib: OR=1.7 (95%CI;1.2-3.6) Rofecoxib: OR=2.4 (95%CI;1.7-3.6)
Beyth 1998^51^ United States Public | 2 Prospective cohort studies (derivation and validation cohorts) using data primarily medical records Derivation cohort of patients who started outpatient warfarin therapy upon discharge from hospital between 1977 and 1983 Validation inception cohort of consecutive patients who started warfarin therapy upon discharge from hospital between 1986 and 1987. Follow-up for both groups was presented up to 4 years. | Derivation cohort: N(cases): 565 (65) Mean age: 61 (SD=14) 47% Male Validation cohort: N(cases): 264 (22) Mean age: 60 (SD=16) 47% Male | Overt bleeding that led to the loss of at least 2.0 units in 7 days or less, or was otherwise life-threatening (eg, intracranial bleeding) | Results from Derivation cohort: [underlined: Risk Index] (Outpatient Bleeding Risk Index)^*^ [underlined: Risk of major bleeding at 12 months] Low: 3% Intermediate: 12% High: 48% [underlined: Warfarin Duration (follow-up time not time on warfarin)] Cumulative events at 1 month: 3% Cumulative events at 12 months: 11 % Cumulative events at 48 months: 22% Results from Validation cohort: [underlined: Risk Index] (Outpatient Bleeding Risk Index)^*^ [underlined: Risk of major bleeding at 12 months] Low: 3% Intermediate: 8% High: 30% [underlined: Warfarin Duration (follow-up time not time on warfarin)] Cumulative events at 1 month: 2% Cumulative events at 12 months: 8 % Cumulative events at 48 months: 12% Results from Combined Cohorts: Stratifying by increased Age and Comorbidity (components of OBRI) shows increased the major bleeding
Bousser 2008^68^ Multi-national Industry | Prospective Cohort (vitamin K antagonist arm of RCT, warfarin or acenocoumarol) Patients with atrial fibrillation at risk for thromboembolism Follow-up 0.9 years (SD=0.5) | N(cases): 2293(29) Mean age: 70.2 (SD=9.1 65% Male | Bleeding that was fatal, intracranial, or affected another critical anatomical site, or overt bleeding with a drop of hemoglobin ≥20 g/L or requiring transfusion of two or more units of Erythrocytes. | [underlined: Risk Index] (CHADS2 score) * Low: 0.8% /PYr Moderate: 1.0% /PYr High: 2.5% /PYr
DiMarco 2005^58^ United States AFFIRM Trial Public | RCT comparing rate-control and rhythm-control strategies in patients with atrial fibrillation All patients were eligible for warfarin at baseline and most continued their warfarin regimen Follow-up average of 3.5 years (range 0 - 5.9 years) | N(cases): 4060 (260) Mean age: 70 (SD=9) 61% Male | Major bleeding was either CNS hemorrhage, or outside the CNS bleeding that required transfusion of ≥2 units of blood, hospitalization in an intensive care unit, and/or discontinuation of anticoagulant or antiplatelet Therapy. | [underlined: Age:] (per year): HR=1.05(95%CI;1.04,1.07)^***^ [underlined: Comorbidities:] CHF: HR=1.43(95%CI;1.09,1.89)^***^ Diabetes: HR=1.44(95%CI;1.07,1.93)^***^ Hepatic or Renal Disease: HR=1.93(95%CI;1.27,2.93)^***^ [underlined: Other Med Use:] Aspirin Use: HR=2.01(95%CI;1.45,2.77)^***^ Rate Control vs. Rhythm-control strategies No difference (p=0.45)
Douketis 2006^62^ Multinational SPORTIF III & V Trials Industry | Pooled analysis of two large RCTs using just the Warfarin arms of each trial Patients were adults with nonvalvular atrial fibrillation Followed up to 24 months | N(cases): 3665 (136) Mean age: ~71 <65: 22% 65-75: 40% >75: 38% 70% Male | Major bleeding was: fatal bleeding; clinically overt bleeding associated with a reduction in hemoglobin level of 20 g/L or more; clinically overt bleeding requiring transfusion of 2 or more units of whole blood or erythrocytes; intracerebral bleeding; and bleeding involving a critical anatomic site. | [underlined: Age:] (Greater 75): HR=1.26(95%CI;1.03,1.52)^***^ [underlined: Comorbidities:] Hepatic Disease: HR=4.88(95%CI;1.55,15.39)^***^ [underlined: Other Med Use:] Aspirin Use: HR=2.41(95%CI;1.69,3.43)^***^ Statins Use: HR=0.60(95%CI;0.41,0.87)^***^ [underlined: Warfarin Duration:]^*^ Cumulative incidence of major bleeding, % (95% CI)^*^ 3 Months: 0.8 (0.5-1.0) 12 Months: 2.6 (2.1-3.2) 24 Months: 4.7 (3.8-5.5)
Douketis 2007^67^ Canada Public | Nested case-control study using administrative databases A patients were age 66+ with atrial fibrillation who were prescribed warfarin between April 1, 1994, and December 31, 2001 Follow-up average of 2 years | N(cases): 16,618 (1518) Mean age: 77 (SD=7) 46% Male | Cases were admitted to a hospital with a diagnosis of upper gastrointestinal or intracranial hemorrhage. | [underlined: Other Med Use:] [underlined: Long-term Warfarin Users (>6 months)] Statins Use: OR=0.82(95%CI;0.67,1.00) *** [underlined: Recent Warfarin Users (<6 months)] Statins Use: OR=1.02(95%CI;0. 78,1.34) ***
Fang 2006^64^ United States ATRIA Study Public | Cohort study using Administrative Datasets Patients with nonvalvular atrial fibrillation Follow-up 2.4 years (IQR=1.8-2.8) | 15,300 person years (170 cases) Mean age: 71 (SD=15) 53% Male | Intracranial hemorrhages unless they were associated with major head trauma (e.g., neurosurgical procedure, motor vehicle accident, and skull fracture). Major extracranial hemorrhages defined as fatal, requiring transfusion of two or more units of packed blood cells, or hemorrhage into a critical anatomic site. | [underlined: New vs. Prior Warfarin] [underlined: Intracranial hemorrhages] 1^st^ Month: 0.92% /PYr Afterward: 0.46% /PYr RR: 2.0 (95% CI ; 0.6–6.7)^*^ [underlined: Major Extracranial hemorrhages] 1^st^ Month: 1.2% /PYr Afterward: 0.61% /PYr RR: 2.0 (95% CI ; 0.7–5.8)^*^ [underlined: Age] [underlined: Intracranial hemorrhages] ≥80 v. <80: RR=1.8 (95%CI;1.1–3.1)^***^ [underlined: Major Extracranial hemorrhages] Per 10 years: RR=1.3 (95%CI;1.1–1.7)^***^
Fang 2005^59^ United States ATRIA Study Public | Cohort study using Administrative Datasets Patients with nonvalvular atrial fibrillation Follow-up 2.4 years (IQR=1.8-2.8) | ~15,000 person years (167 cases) Mean age: 71 (SD=15) 53% Male | Intracranial hemorrhages unless they were associated with major head trauma (e.g., neurosurgical procedure, motor vehicle accident, and skull fracture). Major extracranial hemorrhages defined as fatal, requiring transfusion of two or more units of packed blood cells, or hemorrhage into a critical anatomic site. | [underlined: Gender:] [underlined: All major hemorrhages] Men 1.1% vs. Women 1.0%^*^ Men: RR=1.25 (95% CI;0.91-1.67)^***^ [underlined: Intracranial hemorrhages] Men 0.55% vs. Women 0.36%^*^ Men: RR=2.0 (95% CI;1.11-3.33)^***^
Fihn 1996^49^ United States - VA National Consortium of Anticoagulation Clinics Government + industry | Combined retrospective and prospective cohort studies Patients attending a combination of VA and university-affiliated clinics anticoagulation clinic between 1980 and 1993 Follow-up: Retrospective study data from 1980 to 1990; prospective study data collected between 1990 and 1993. | N(cases): 2376(259) Mean age: 58.3 73.4% Male | Overt gastrointestinal bleeding; occult gastrointestinal bleeding if endoscopic or radiographic studies were done; gross hematuria prompting cytoscopy or intravenous urography or lasted more than 2 days; hemoptysis. | [underlined: Age group] *
Fihn 1996^49^ United States - VA National Consortium of Anticoagulation Clinics Government + industry | | N(cases): 2376(259) Mean age: 58.3 73.4% Male | | [underlined: Serious Bleeding] | | [underlined: RR(95%CI)] *
Fihn 1996^49^ United States - VA National Consortium of Anticoagulation Clinics Government + industry | | N(cases): 2376(259) Mean age: 58.3 73.4% Male | | <50 yrs: | 9.3%/PYr | ref
Fihn 1996^49^ United States - VA National Consortium of Anticoagulation Clinics Government + industry | | N(cases): 2376(259) Mean age: 58.3 73.4% Male | | 50-59 yrs: | 7.1%/PYr | 1.2 (0.9-1.6)
Fihn 1996^49^ United States - VA National Consortium of Anticoagulation Clinics Government + industry | | N(cases): 2376(259) Mean age: 58.3 73.4% Male | | 60-69 yrs: | 6.6%/PYr | 1.3 (1.0-1.7)
Fihn 1996^49^ United States - VA National Consortium of Anticoagulation Clinics Government + industry | | N(cases): 2376(259) Mean age: 58.3 73.4% Male | | 70-79 yrs: | 5.1%/PYr | 1.3 (1.0-1.7)
Fihn 1996^49^ United States - VA National Consortium of Anticoagulation Clinics Government + industry | | N(cases): 2376(259) Mean age: 58.3 73.4% Male | | 80-89 yrs: | 4.4%/PYr | 0.9 (0.5-1.5)
Fihn 1996^49^ United States - VA National Consortium of Anticoagulation Clinics Government + industry | | N(cases): 2376(259) Mean age: 58.3 73.4% Male | | [underlined: Life-threatening or fatal] | | [underlined: RR(95%CI)] *
Fihn 1996^49^ United States - VA National Consortium of Anticoagulation Clinics Government + industry | | N(cases): 2376(259) Mean age: 58.3 73.4% Male | | <50 yrs: | 0.8%/PYr | ref
Fihn 1996^49^ United States - VA National Consortium of Anticoagulation Clinics Government + industry | | N(cases): 2376(259) Mean age: 58.3 73.4% Male | | 50-59 yrs: | 1.3%/PYr | 1.3 (0.4-4.1)
Fihn 1996^49^ United States - VA National Consortium of Anticoagulation Clinics Government + industry | | N(cases): 2376(259) Mean age: 58.3 73.4% Male | | 60-69 yrs: | 1.1%/PYr | 1.5 (0.5-4.0)
Fihn 1996^49^ United States - VA National Consortium of Anticoagulation Clinics Government + industry | | N(cases): 2376(259) Mean age: 58.3 73.4% Male | | 70-79 yrs: | 0.7%/PYr | 0.9 (0.3-3.1)
Fihn 1996^49^ United States - VA National Consortium of Anticoagulation Clinics Government + industry | | N(cases): 2376(259) Mean age: 58.3 73.4% Male | | 80-89 yrs: | 3.4%/PYr | 4.5 (1.3-15.6)
Flaker 2006^63^ Multinational SPORTIF III & V Trials Industry | Randomized multicenter study (combined open-label and double-blinded studies) High-risk patients with nonvalvular AF Follow-up: 1.4 years (16.5 months) average treatment exposure | N(cases): 3653(125) Mean age: ~71 70% Male | Fatal; involved a critical anatomical site; or overt and associated with a decrease in hemoglobin level of 20 g/L or transfusion of at least 2 U of blood. | [underlined: Warfarin vs Warfarin +aspirin (p=.01)]^*^ Warfarin (n/N): 2.3% (100/3172) Warfarin + aspirin (n/N): 3.9% (25/481)
Gage 2006^80^ United States NRAF Study Public | Cohort study using medical records from the National registry of Atrial Fibrillation data set. Medicare patients with confirmed atrial fibrillation Follow-up to a maximum of 1000 days after baseline hospitalization | N(cases): 1604(67) Mean age: ~80 ~43% Male | Major bleeding defined using ICD-9-CM codes | [underlined: Risk Index (HEMORR _2_ HAGES)] Bleeds per 100 patient-years (95%CI) Score: 0: 1.9 (0.6-4.4) 1: 2.5 (1.3-4.3) 2: 5.3 (3.4-8.1) 3: 8.4 (4.9-13.6) 4: 10.4 (5.1-18.9) ≥5: 12.3 (5.8-23.1) [underlined: Risk Index (OBRI):] Low: 1.1 (0.3-4.3) Moderate: 4.9 (3.6-6.5) High: 8.8 (5.6-14.0) [underlined: Risk Index (Kuijer 1999):] Low: 2.9 (1.3-6.5) Moderate: 5.2 (4.0-6.7) High: 7.5 (2.8-19.9) [underlined: Risk Index (Kearon 2003):] Score: 0: 2.5 (1.1-6.1) 1: 2.5 (1.4-4.3) 2: 6.5 (4.5-9.4) 3: 9.3 (5.7-15.3) ≥4: 15.3 (6.4-36.8)
Gasse 2005^60^ UK Government + industry | Longitudinal cohort study plus a nested case-control analysis Patients (from the UK General Practice research Database) who had a first ever warfarin prescription for AF during the study period and continued treatment for more than 90 days Follow-up was approximately 1 year (3740.8 patient-years of warfarin exposure) | N(cases): 4152(46) Age range: ~70 58% Male | Idiopathic bleeds that resulted in hospitalization within 30 days or death within 7 days following bleeding event | [underlined: Warfarin +concomitant drug [incidence rate = cases/100 PYAR]]^*^ Total: 1.2 Warfarin alone: 0.9 Concomitant (all): 1.8 Allopurinol: 3.4 Amiodarone: 1.2 Aspirin: 2.4 Levothyroxine: 0.9 Metronidazole: 38.5 Miconazole: 41.7 Omeprazole: 3.2 Paracetamol: 3.8 Paracetamol + Dextropropoxyphene: 4.1
Gomberg-Maitland 2006^65^ Multinational SPORTIF III & V Trials Industry | Randomized multicenter study (combined open-label and double-blinded studies) High-risk patients with nonvalvular AF Followed up to 24 months | N(cases): 3624 (NA) Mean age: ~71 69.7% Male | Major bleeding | [underlined: Warfarin arm]^*^ Women vs men: -0.35%/yr difference (P=0.491) Men: 91 events, 2.57%/yr Women ≥ 75: 2.60%/yr Women < 75: 1.83%/yr
Hart 1999^53^ Meta-analysis | Meta-analysis of 6 randomized trials of warfarin vs aspirin + warfarin. All published prior to 1998 none of which were largest alone to be included Patients with prosthetic cardiac valves (4 trials), men with coronary risk factors (1 trial), patients with AF (1 trial) Follow-up: | N(cases): 3874(31) Mean age: NA NA % Male | Intracranial hemorrhage | [underlined: Warfarin vs Warfarin +aspirin (p=.08)]^*^ Warfarin (n/N): 0.46% (9/1947) Warfarin + aspirin (n/N): 1.14% (22/1927)
Healey 2008^69^ [ACTIVE-W] Multinational Industry | Prospective randomized study (warfarin arm of RCT) Patients with AF and at least 1 additional risk factor for stroke Followed up to 24 months (median 1.3 years) | N(cases): 3371 (93) Mean age: 70.2 (SD=9.5) 66% Male | Bleeding associated with: death; drop in hemoglobin of at least 2 g/dL; significant hypotension with the need for inotropic agents bleeding requiring surgical intervention (other than vascular site repair); symptomatic intracranial hemorrhage; intraocular hemorrhage causing loss of vison; or the requirement for a transfusion of at least 2 U of blood. | [underlined: Risk Index] (CHADS2 score)^*^ 0: 0.00/100 pt-yrs 1: 1.48/100 pt-yrs 2: 2.89/100 pt-yrs 3: 2.58/100 pt-yrs 4: 2.92/100 pt-yrs 5: 0.90/100 pt-yrs 6: 6.85/100 pt-yrs CHADS2=1: 1.36%/yr CHADS2>1: 2.75%/yr [underlined: OAC-naïve]^*^ CHADS2=1: 1.81%/yr CHADS2>1: 3.76%/yr [underlined: OAC-experienced]^*^ CHADS2=1 133%/yr CHADS2>1: 2.47%/yr
Higashi 2002^54^ United States UWMC Clinics Government + industry | Retrospective cohort study Patients attending Univ of Washington Med Ctr anticoagulation clinics Follow-up: 2.2 years (mean) | N(cases): 185(28) Mean age: 59.9 (SD=15.7) 63.8% Male | Serious bleeding: overt gastrointestinal bleeding; occult gastrointestinal bleeding if endoscopic or radiographic studies were performed; gross hematuria that prompted cystoscopy or intravenous urography or lasted more than 2 days; hemoptysis; blood transfusions of 2 units or more. | [underlined: CYP2C9 Genotype]^*^ Variant: 10.92% /PYr Wild-type: 4.89% /PYr
Johnson 2008^70^ United States Public | Retrospective longitudinal cohort study: warfarin vs warfarin + antiplatelet combination therapy Patients attending Kaiser Permanente Colorado anticoagulation clinics Follow-up: 4.6 yr (SD=4.0) | N (cases): 4183(55) Mean age: 70.7 (SD=12.5 53.3% Male | Major hemorrhage: required the transfusion of two or more units of RBCs; caused a decrease in hemoglobin concentration of ≥ 2 g/dL; or involved any intracranial, intraarticular, intraocular, or retroperitoneal sites | [underlined: Warfarin vs Warfarin + antiplatelet (p=.003)]^*^ Warfarin (n/N): 0.9% (23/2560) Warfarin + antiplatelet (n/N): 2.0% (32/1623)
Le Tourneau 2009^81^ United States Public | Population-based retrospective cohort study with chart review Patients in Olmsted County, MN who had mechanical mitral value replacement Follow-up: 8.2 yr (SD=6.1) | N (cases): 112(27) Mean age: 57 (SD=16) 40% Male | Bleeding causing death, hospitalization, permanent injury or transfusion | [underlined: Cancer] HR 4.01 (95%CI; 1.89-8.52) ** [underlined: INR SD (Variability)] HR 2.48 (95%CI; 1.11-5.55) **
Limdi 2008^71^ United States POAT Study Public | Prospective cohort study: influence of genotypes on risk for hemorrhagic complications Patients participating in the Pharmacogenetic Optimization of Anticoagulation Therapy (POAT) cohort study Follow-up: 14.9 mo (SD=10.7) | N(cases): 446(44) Mean age: 60.6 (SD=15.6) 51.3% Male 50.9% African American | Major hemorrhage | [underlined: Incidence rate by genotype]^*^ [underlined: CYP2C9] Total: 7.93/100 PYr Wild type: 5.67/100PYr Variant: 15.74/100 PYr [underlined: VKORC1 1173C/T] Total: 8.0/100 PYr “CC”: 7.4/100 PYr Any “T”: 8.9/100 PYr
Limdi 2009^75^ United States POAT Study Public | Secondary analysis of a prospective cohort study: influence of kidney function on risk for hemorrhagic complications Patients participating in the Pharmacogenetic Optimization of Anticoagulation Therapy (POAT) cohort study Follow-up: 16.2 mo (mean) | N(cases): 565(64) Mean age: 61 (SD=16) 51.1% Male 47.6% African American | Major hemorrhage | [underlined: Incidence rate by GFR]^*^ Overall: 8.4/100 PYr GFR≥60: 6.2/100 PYr GFR=30-59: 8.3/100 PYr GFR<30: 30.5/100 PYr
Lind 2009^77^ Sweden Public | Prospective cohort study Patients with at least at 3 month duration treatment plan were recruited from several warfarin clinics Follow-up: 4.2 years | N(cases): 719(73) Mean age: 70 (SD=11) 63% Male | Fatal bleeding and/or symptomatic bleeding in a critical area or organ and/or bleeding causing a fall in hemoglobin level of 2 g/dL or more | [underlined: Unadjusted] [underlined: Gender:]^*^ Men: RR=0.8 (95% CI;0.5–1.2) [underlined: hsCRP:]^*^ Per 1 SD: 1.0 (95% CI;0.8–1.3) [underlined: MV Adjusted] [underlined: Age]^***^ Per 10 years: RR=1.4 (95%CI;1.1–1.7) [underlined: Thrombomodulin]:^***^ Per 1 SD: 1.4 (95% CI;1.2–1.7)
Lindh 2008^72^ Sweden WARG (Warfarin Genetics) study Public and Industry | Prospective cohort with nested case-control for association of INR and severe bleeding risk No restriction on indication for warfarin treatment Starting warfarin treatment or on anticoagulant for < 2 wks Study period: 12/2001 – 8/2005 1276 patient-years follow-up | N(cases): 1523(33 in 29 patients) Median (interquartile range) age: 66 (57; 74) 63% Male | WHO criteria: lethal, life-threatening, permanently disabling, or leading to hospital admission (ED admissions excluded) or prolongation of hospital stay | [underlined: First 165 days of treatment vs. beyond 165] RR 1.1 (95%CI; 0.5-2.3) [underlined: First treatment month vs. beyond 1 month] RR 2.4 (95%CI; 1.0-6.0) [underlined: Age] HR 1.02 (95%CI; 0.98-1.06)^***^ [underlined: Male sex] HR 2.8 (95%CI; 1.1-7.3)^***^ [underlined: Target INR] HR 1.3 (95%CI; 0.03-50)^***^ [underlined: Aver. Warfarin Dose (mg/d)] HR 0.97 (95%CI; 0.79-1.2)^***^ [underlined: Time Outside Ther INR interval] HR 1.2 (95%CI; 0.95-1.5)^***^ [underlined: Interacting drugs at start of tx (yes/no)] HR 2.3 (95%CI; 1.1-4.9)^***^ [underlined: INR at time of event (28cases;56 controls)] OR 1.9 (95%CI; 1.1-3.4)
McMahan 1998^52^ United States, Veteran's Affairs Medical Center Funding NR | Retrospective cohort No restriction on indication for warfarin therapy Most recent course of treatment (if multiple courses) Followed from start of treatment at VAMC between 3/31/89 and 3/31/94 to end of treatment or 7/1/94; mean duration of follow-up 14.0 mos (range: 1 day to 60 mos) | N(cases): 565(40) Mean Age 65.1 (SD=10.9) 98.5% Male | Landefeld's bleeding severity index - major hemorrhage defined based on patient survival, amount of blood lost, and physical consequences of the hemorrhage | [underlined: GI bleeding] RR 2.1 (95%CI; 0.93-4.9) *** [underlined: Comorbid Condition] RR 1.6 (95%CI; 0.86-3.1) *** [underlined: Stroke] RR 1.2 (95%CI; 0.50-2.9) *** [underlined: Age ≥65 yrs] RR 1.0 (95%CI; 0.53-1.9) *** [underlined: Atrial Fibrillation] RR 1.0 (95%CI; 0.47-2.1) *** [underlined: Alcohol abuse] RR 2.7 (95%CI; 1.4-5.4) *** [underlined: Chronic renal insufficiency] RR 2.6 (95%CI; 1.3-5.2) *** [underlined: Previous GI bleed] RR 2.4 (95%CI;1.1-6.0) *** NOTE: other factor not significant in univariate analyses include: gender(p=.63), NSAID (p=.78), aspirin (p=.56), diabetes (p=.27)
Meckley 2008^73^ United States UWMC Clinics Government + industry | Retrospective cohort of patients attending Univ of Washington Med Ctr anticoagulation clinics No restriction on indication for warfarin therapy; had known CYP2C9 and VKORC1 genotype status Attended anticoagulation clinic between 4/3/90 and 4/21/01 with confirmed initial warfarin exposure date and at least 2 clinic visits Excluded Asian or African race | N(cases): 172(31) Mean age: 59.8 64.5% Male | Serious and life-threatening bleeds according to Fihn, 1993 definition | [underlined: Genetics] *** [underlined: CYP2C9 (Variant vs] Wild-type) HR 3.18 (95%CI; 1.30-7.78) [underlined: VKORC1] (vs. AB) [underlined: AA:] HR 1.21 (95%CI; 0.38-3.82) [underlined: BB:] HR 0.83 (95%CI; 0.33-2.09)
Metlay 2008^74^ United States Public | Prospective cohort No restriction on indication for warfarin therapy New and continuing users of warfarin; over age 65 Recruited between 5/1/02 and 5/31/03; 24 month follow-up | N(cases): 2370 (111) Mean age: ~78 (all over 65) 23% Male | Any hospitalization due to warfarin-related bleeding (meeting specified criteria and reviewed by independent reviewers) | [underlined: Duration of Warfarin Use]^*^ [underlined: New users of warfarin:] 4.5 /100 PY (95% CI; 2.9-6.8) [underlined: Chronic users of warfain:] 4.7/100PY (95%CI;3.7-5.8) [underlined: First month of follow-up vs. all other months:]^*^ RR 0.9 (95%CI; 0.4-1.8) [underlined: Age] No association^***^ [underlined: Meds] [underlined: NSAID/ASA (vs. neither)]^***^ RR 1.4 (95%CI; 0.9-2.1) [underlined: Number of Current medications (vs. 1-3 meds)]^***^ 4-8 Meds: RR 1.5 (95%CI; 0.8-3.0) ≥9 Meds: RR 2.2 (95%CI; 1.0-4.6) [underlined: Primary Indication]^***^ [underlined: Valve condition requiring warfarin (vs. other indications):] RR 3.02 (95%CI; 1.91-4.78) [underlined: Anticoagulation clinic (vs. non-specialized clinic):] RR 1.63 (95%CI 0.84-3.14)
Poli 2009b78 Italy Funding NR | Prospective cohort Atrial fibrillation Referred to anticoagulation clinic between 6/98 and 12/07 2,365 pt/years follow-up; median time of follow-up 3.1 years (range: 3 mos-9.5 yrs) | N(cases): 662 (32 with 17 cerebral) Median age: 75 yrs (range: 49-94) 64% Male | Fatal, intracranial, ocular causing blindness, articular, or retroperitoneal; surgery or transfusion of >2 blood units required; hemoglobin reduced 2 g/ dl or more | [underlined: Risk Index (AFI):] * Low: 0 Moderate: 1.3/100 PY High: 1.4/100 PY [underlined: Risk Index (ACCP):] * Low: 0 Moderate: 0 High 1.4/100 PY [underlined: Risk Index (CHADS2):] * Low: 0 Moderate: 1.0/100 PY High: 1.9/100 PY [underlined: Risk Index (NICE):] Low: 0 Moderate: 1.0/100 PY High: 1.5/100 PY
Poli 2009a76 Italy Funding NR | Prospective cohort Atrial fibrillation Referred to anticoagulation clinic between 6/98 and 12/07 2,567 pt/years follow-up; mean time of follow-up 2.7 years (range: 0.1 -13 yrs) | N(cases): 783 (37 with 20 cerebral) Median age: 75 yrs (range: 37-94) 65% Male | Fatal, intracranial, ocular causing blindness, articular, or retroperitoneal; surgery or transfusion of >2 blood units required; hemoglobin reduced 2 g/ dl or more | [underlined: Age:]^*^ [underlined: Major bleeding] ≥80 v. <80: RR=1.9 (95%CI;1.2-2.8) [underlined: Cerebral bleeding] ≥80 v. <80: RR=2.1 (95%CI;0.8-5.5)
Schauer 2005^61^ United States Public | Retrospective cohort Nonvalvular atrial fibrillation Ohio Medicaid patients; 1/1/97 to 5/31/02 Mean follow-up 740 days | N(cases): 9,345 (1022) Mean age: 72 (SD=13.8) 32% Male | Intracranial hemorrhage, and gastrointestinal bleeding requiring hospitalization | [underlined: Intracranial Hemorrhage:]
Schauer 2005^61^ United States Public | Retrospective cohort Nonvalvular atrial fibrillation Ohio Medicaid patients; 1/1/97 to 5/31/02 Mean follow-up 740 days | N(cases): 9,345 (1022) Mean age: 72 (SD=13.8) 32% Male | Intracranial hemorrhage, and gastrointestinal bleeding requiring hospitalization | | | HR (95% CI)
Schauer 2005^61^ United States Public | Retrospective cohort Nonvalvular atrial fibrillation Ohio Medicaid patients; 1/1/97 to 5/31/02 Mean follow-up 740 days | N(cases): 9,345 (1022) Mean age: 72 (SD=13.8) 32% Male | Intracranial hemorrhage, and gastrointestinal bleeding requiring hospitalization | Substance abuse | | 2.4 (1.4, 4.0)^***^
Schauer 2005^61^ United States Public | Retrospective cohort Nonvalvular atrial fibrillation Ohio Medicaid patients; 1/1/97 to 5/31/02 Mean follow-up 740 days | N(cases): 9,345 (1022) Mean age: 72 (SD=13.8) 32% Male | Intracranial hemorrhage, and gastrointestinal bleeding requiring hospitalization | Psychiatric illness | | 1.5 (1.0, 2.1) ***
Schauer 2005^61^ United States Public | Retrospective cohort Nonvalvular atrial fibrillation Ohio Medicaid patients; 1/1/97 to 5/31/02 Mean follow-up 740 days | N(cases): 9,345 (1022) Mean age: 72 (SD=13.8) 32% Male | Intracranial hemorrhage, and gastrointestinal bleeding requiring hospitalization | Social risk factors | | 0.9 (0.7, 1.3) *
Schauer 2005^61^ United States Public | Retrospective cohort Nonvalvular atrial fibrillation Ohio Medicaid patients; 1/1/97 to 5/31/02 Mean follow-up 740 days | N(cases): 9,345 (1022) Mean age: 72 (SD=13.8) 32% Male | Intracranial hemorrhage, and gastrointestinal bleeding requiring hospitalization | Hypertension | | 1.4 (0.9, 2.2) *
Schauer 2005^61^ United States Public | Retrospective cohort Nonvalvular atrial fibrillation Ohio Medicaid patients; 1/1/97 to 5/31/02 Mean follow-up 740 days | N(cases): 9,345 (1022) Mean age: 72 (SD=13.8) 32% Male | Intracranial hemorrhage, and gastrointestinal bleeding requiring hospitalization | CHF | | 0.9 (0.6, 1.2) *
Schauer 2005^61^ United States Public | Retrospective cohort Nonvalvular atrial fibrillation Ohio Medicaid patients; 1/1/97 to 5/31/02 Mean follow-up 740 days | N(cases): 9,345 (1022) Mean age: 72 (SD=13.8) 32% Male | Intracranial hemorrhage, and gastrointestinal bleeding requiring hospitalization | Diabetes mellitus | | 0.9 (0.7, 1.3) *
Schauer 2005^61^ United States Public | Retrospective cohort Nonvalvular atrial fibrillation Ohio Medicaid patients; 1/1/97 to 5/31/02 Mean follow-up 740 days | N(cases): 9,345 (1022) Mean age: 72 (SD=13.8) 32% Male | Intracranial hemorrhage, and gastrointestinal bleeding requiring hospitalization | Liver disease | | 0.9 (0.4, 2.0) *
Schauer 2005^61^ United States Public | Retrospective cohort Nonvalvular atrial fibrillation Ohio Medicaid patients; 1/1/97 to 5/31/02 Mean follow-up 740 days | N(cases): 9,345 (1022) Mean age: 72 (SD=13.8) 32% Male | Intracranial hemorrhage, and gastrointestinal bleeding requiring hospitalization | Renal disease | | 1.3 (0.9, 1.9) *
Schauer 2005^61^ United States Public | Retrospective cohort Nonvalvular atrial fibrillation Ohio Medicaid patients; 1/1/97 to 5/31/02 Mean follow-up 740 days | N(cases): 9,345 (1022) Mean age: 72 (SD=13.8) 32% Male | Intracranial hemorrhage, and gastrointestinal bleeding requiring hospitalization | DVT | | 0.9 (0.6, 1.5) *
Schauer 2005^61^ United States Public | Retrospective cohort Nonvalvular atrial fibrillation Ohio Medicaid patients; 1/1/97 to 5/31/02 Mean follow-up 740 days | N(cases): 9,345 (1022) Mean age: 72 (SD=13.8) 32% Male | Intracranial hemorrhage, and gastrointestinal bleeding requiring hospitalization | Age (per decade) | | 1.0 (0.9, 1.2) *
Schauer 2005^61^ United States Public | Retrospective cohort Nonvalvular atrial fibrillation Ohio Medicaid patients; 1/1/97 to 5/31/02 Mean follow-up 740 days | N(cases): 9,345 (1022) Mean age: 72 (SD=13.8) 32% Male | Intracranial hemorrhage, and gastrointestinal bleeding requiring hospitalization | Sex, male | | 1.1 (0.8, 1.5) *
Schauer 2005^61^ United States Public | Retrospective cohort Nonvalvular atrial fibrillation Ohio Medicaid patients; 1/1/97 to 5/31/02 Mean follow-up 740 days | N(cases): 9,345 (1022) Mean age: 72 (SD=13.8) 32% Male | Intracranial hemorrhage, and gastrointestinal bleeding requiring hospitalization | Race, white | | 0.8 (0.6, 1.2) *
Schauer 2005^61^ United States Public | Retrospective cohort Nonvalvular atrial fibrillation Ohio Medicaid patients; 1/1/97 to 5/31/02 Mean follow-up 740 days | N(cases): 9,345 (1022) Mean age: 72 (SD=13.8) 32% Male | Intracranial hemorrhage, and gastrointestinal bleeding requiring hospitalization | [underlined: GI Bleeding:]
Schauer 2005^61^ United States Public | Retrospective cohort Nonvalvular atrial fibrillation Ohio Medicaid patients; 1/1/97 to 5/31/02 Mean follow-up 740 days | N(cases): 9,345 (1022) Mean age: 72 (SD=13.8) 32% Male | Intracranial hemorrhage, and gastrointestinal bleeding requiring hospitalization | | | HR (95% CI)
Schauer 2005^61^ United States Public | Retrospective cohort Nonvalvular atrial fibrillation Ohio Medicaid patients; 1/1/97 to 5/31/02 Mean follow-up 740 days | N(cases): 9,345 (1022) Mean age: 72 (SD=13.8) 32% Male | Intracranial hemorrhage, and gastrointestinal bleeding requiring hospitalization | Substance abuse | | 1.4 (1.1, 1.9)^***^
Schauer 2005^61^ United States Public | Retrospective cohort Nonvalvular atrial fibrillation Ohio Medicaid patients; 1/1/97 to 5/31/02 Mean follow-up 740 days | N(cases): 9,345 (1022) Mean age: 72 (SD=13.8) 32% Male | Intracranial hemorrhage, and gastrointestinal bleeding requiring hospitalization | Psychiatric illness | | 1.2 (1.0, 1.4) ***
Schauer 2005^61^ United States Public | Retrospective cohort Nonvalvular atrial fibrillation Ohio Medicaid patients; 1/1/97 to 5/31/02 Mean follow-up 740 days | N(cases): 9,345 (1022) Mean age: 72 (SD=13.8) 32% Male | Intracranial hemorrhage, and gastrointestinal bleeding requiring hospitalization | Social risk factors | | 1.3 (1.1, 1.5) ***
Schauer 2005^61^ United States Public | Retrospective cohort Nonvalvular atrial fibrillation Ohio Medicaid patients; 1/1/97 to 5/31/02 Mean follow-up 740 days | N(cases): 9,345 (1022) Mean age: 72 (SD=13.8) 32% Male | Intracranial hemorrhage, and gastrointestinal bleeding requiring hospitalization | Hypertension | | 1.1 (1.0, 1.3) *
Schauer 2005^61^ United States Public | Retrospective cohort Nonvalvular atrial fibrillation Ohio Medicaid patients; 1/1/97 to 5/31/02 Mean follow-up 740 days | N(cases): 9,345 (1022) Mean age: 72 (SD=13.8) 32% Male | Intracranial hemorrhage, and gastrointestinal bleeding requiring hospitalization | CHF | | 1.3 (1.1, 1.6) ***
Schauer 2005^61^ United States Public | Retrospective cohort Nonvalvular atrial fibrillation Ohio Medicaid patients; 1/1/97 to 5/31/02 Mean follow-up 740 days | N(cases): 9,345 (1022) Mean age: 72 (SD=13.8) 32% Male | Intracranial hemorrhage, and gastrointestinal bleeding requiring hospitalization | Diabetes | | 1.0 (0.9, 1.2) ***
Schauer 2005^61^ United States Public | Retrospective cohort Nonvalvular atrial fibrillation Ohio Medicaid patients; 1/1/97 to 5/31/02 Mean follow-up 740 days | N(cases): 9,345 (1022) Mean age: 72 (SD=13.8) 32% Male | Intracranial hemorrhage, and gastrointestinal bleeding requiring hospitalization | Liver disease | | 1.3 (1.0, 1.7) ***
Schauer 2005^61^ United States Public | Retrospective cohort Nonvalvular atrial fibrillation Ohio Medicaid patients; 1/1/97 to 5/31/02 Mean follow-up 740 days | N(cases): 9,345 (1022) Mean age: 72 (SD=13.8) 32% Male | Intracranial hemorrhage, and gastrointestinal bleeding requiring hospitalization | Renal disease | | 1.6 (1.4, 1.9) ***
Schauer 2005^61^ United States Public | Retrospective cohort Nonvalvular atrial fibrillation Ohio Medicaid patients; 1/1/97 to 5/31/02 Mean follow-up 740 days | N(cases): 9,345 (1022) Mean age: 72 (SD=13.8) 32% Male | Intracranial hemorrhage, and gastrointestinal bleeding requiring hospitalization | DVT | | 1.2 (1.0, 1.5) ***
Schauer 2005^61^ United States Public | Retrospective cohort Nonvalvular atrial fibrillation Ohio Medicaid patients; 1/1/97 to 5/31/02 Mean follow-up 740 days | N(cases): 9,345 (1022) Mean age: 72 (SD=13.8) 32% Male | Intracranial hemorrhage, and gastrointestinal bleeding requiring hospitalization | Age (per decade) | | 1.0 (1.0, 1.1) *
Schauer 2005^61^ United States Public | Retrospective cohort Nonvalvular atrial fibrillation Ohio Medicaid patients; 1/1/97 to 5/31/02 Mean follow-up 740 days | N(cases): 9,345 (1022) Mean age: 72 (SD=13.8) 32% Male | Intracranial hemorrhage, and gastrointestinal bleeding requiring hospitalization | Sex, male | | 1.1 (0.9, 1.2) *
Schauer 2005^61^ United States Public | Retrospective cohort Nonvalvular atrial fibrillation Ohio Medicaid patients; 1/1/97 to 5/31/02 Mean follow-up 740 days | N(cases): 9,345 (1022) Mean age: 72 (SD=13.8) 32% Male | Intracranial hemorrhage, and gastrointestinal bleeding requiring hospitalization | Race, white | | 0.9 (0.7, 1.0) *
Schelleman 2010^79^ United States Non-profit | Case-control study nested within the Medicaid programs Evaluating new antihyperlipidemic prescriptions in patients on warfarin for at least 90 days California, Florida, New York, Ohio, and Pennsylvania Medicaid patients from 1999 to 2003 Average follow-up appears to be nearly 1 year | Total N=353,489 Cases=12,193 Mean age: ~69 33% Male | ICD-9 code indicating hospitalization for gastrointestinal bleeding. | | GI Bleeding
Schelleman 2010^79^ United States Non-profit | | Total N=353,489 Cases=12,193 Mean age: ~69 33% Male | ICD-9 code indicating hospitalization for gastrointestinal bleeding. | New Prescription | OR (95% CI)^***^
Schelleman 2010^79^ United States Non-profit | | Total N=353,489 Cases=12,193 Mean age: ~69 33% Male | ICD-9 code indicating hospitalization for gastrointestinal bleeding. | Fenofibrate | No data
Schelleman 2010^79^ United States Non-profit | | Total N=353,489 Cases=12,193 Mean age: ~69 33% Male | ICD-9 code indicating hospitalization for gastrointestinal bleeding. | Gemfibrozil | 1.96 (1.19-3.24)
Schelleman 2010^79^ United States Non-profit | | Total N=353,489 Cases=12,193 Mean age: ~69 33% Male | ICD-9 code indicating hospitalization for gastrointestinal bleeding. | Fluvastatin | 1.45 (0.68-3.09)
Schelleman 2010^79^ United States Non-profit | | Total N=353,489 Cases=12,193 Mean age: ~69 33% Male | ICD-9 code indicating hospitalization for gastrointestinal bleeding. | Simvastatin | 1.33 (1.00-1.78)
Schelleman 2010^79^ United States Non-profit | | Total N=353,489 Cases=12,193 Mean age: ~69 33% Male | ICD-9 code indicating hospitalization for gastrointestinal bleeding. | Atorvastatin | 1.29 (1.04-1.61)
Schelleman 2010^79^ United States Non-profit | | Total N=353,489 Cases=12,193 Mean age: ~69 33% Male | ICD-9 code indicating hospitalization for gastrointestinal bleeding. | Pravastatin | 0.66 (0.38-1.14)
Schelleman 2010^79^ United States Non-profit | | Total N=353,489 Cases=12,193 Mean age: ~69 33% Male | ICD-9 code indicating hospitalization for gastrointestinal bleeding. | 3^rd^ to 4th Prescription | OR (95% CI)^***^
Schelleman 2010^79^ United States Non-profit | | Total N=353,489 Cases=12,193 Mean age: ~69 33% Male | ICD-9 code indicating hospitalization for gastrointestinal bleeding. | Fenofibrate | 1.31 (0.62-2.79)
Schelleman 2010^79^ United States Non-profit | | Total N=353,489 Cases=12,193 Mean age: ~69 33% Male | ICD-9 code indicating hospitalization for gastrointestinal bleeding. | Gemfibrozil | 1.23 (0.61-2.48)
Schelleman 2010^79^ United States Non-profit | | Total N=353,489 Cases=12,193 Mean age: ~69 33% Male | ICD-9 code indicating hospitalization for gastrointestinal bleeding. | Fluvastatin | No data
Schelleman 2010^79^ United States Non-profit | | Total N=353,489 Cases=12,193 Mean age: ~69 33% Male | ICD-9 code indicating hospitalization for gastrointestinal bleeding. | Simvastatin | 1.10 (0.79-1.53)
Schelleman 2010^79^ United States Non-profit | | Total N=353,489 Cases=12,193 Mean age: ~69 33% Male | ICD-9 code indicating hospitalization for gastrointestinal bleeding. | Atorvastatin | 0.62 (0.46-0.85)
Schelleman 2010^79^ United States Non-profit | | Total N=353,489 Cases=12,193 Mean age: ~69 33% Male | ICD-9 code indicating hospitalization for gastrointestinal bleeding. | Pravastatin | 0.54 (0.29-1.01)
Schelleman 2010^79^ United States Non-profit | | Total N=353,489 Cases=12,193 Mean age: ~69 33% Male | ICD-9 code indicating hospitalization for gastrointestinal bleeding. | | OR (95% CI)^*^
Schelleman 2010^79^ United States Non-profit | | Total N=353,489 Cases=12,193 Mean age: ~69 33% Male | ICD-9 code indicating hospitalization for gastrointestinal bleeding. | Male sex | 0.95 (0.92-0.99)
Schelleman 2010^79^ United States Non-profit | | Total N=353,489 Cases=12,193 Mean age: ~69 33% Male | ICD-9 code indicating hospitalization for gastrointestinal bleeding. | Age, (ref=<50)
Schelleman 2010^79^ United States Non-profit | | Total N=353,489 Cases=12,193 Mean age: ~69 33% Male | ICD-9 code indicating hospitalization for gastrointestinal bleeding. | 50-59 | 1.43 (1.32-1.56)
Schelleman 2010^79^ United States Non-profit | | Total N=353,489 Cases=12,193 Mean age: ~69 33% Male | ICD-9 code indicating hospitalization for gastrointestinal bleeding. | 60-69 | 1.81 (1.68-1.96)
Schelleman 2010^79^ United States Non-profit | | Total N=353,489 Cases=12,193 Mean age: ~69 33% Male | ICD-9 code indicating hospitalization for gastrointestinal bleeding. | 70-79 | 2.14 (1.99-2.30)
Schelleman 2010^79^ United States Non-profit | | Total N=353,489 Cases=12,193 Mean age: ~69 33% Male | ICD-9 code indicating hospitalization for gastrointestinal bleeding. | 80+ | 2.34 (2.18-2.51)
Schelleman 2010^79^ United States Non-profit | | Total N=353,489 Cases=12,193 Mean age: ~69 33% Male | ICD-9 code indicating hospitalization for gastrointestinal bleeding. | Prior GI bleed | 3.12 (3.00-3.24)
Schelleman 2010^79^ United States Non-profit | | Total N=353,489 Cases=12,193 Mean age: ~69 33% Male | ICD-9 code indicating hospitalization for gastrointestinal bleeding. | Diabetes | 1.62 (1.56-1.68)
Schelleman 2010^79^ United States Non-profit | | Total N=353,489 Cases=12,193 Mean age: ~69 33% Male | ICD-9 code indicating hospitalization for gastrointestinal bleeding. | Liver disease | 1.79 (1.72-1.87)
Schelleman 2010^79^ United States Non-profit | | Total N=353,489 Cases=12,193 Mean age: ~69 33% Male | ICD-9 code indicating hospitalization for gastrointestinal bleeding. | CKD | 2.57 (2.47-2.68)
Shireman 2006^66^ United States Non-profit | Retrospective Cohort Atrial fibrillation All patients ≥ 65 years old; discharged from hospital receiving warfarin therapy between 4/98 and 3/99 and between 7/00 and 6/01 | Total N=26,345(~415) Development cohort n=19,875(~318) Validation cohort n=6,470(~97) Mean age: 88% 70 years or older 47% Male | Hospitalized for major acute bleeding event (GI hemorrhage, intracranial hemorrhage) (NOTE: only included events within 90 days of discharge from index AF admission and only the first event for a subject) | [underlined: Results from Development Cohort] [underlined: Age ≥ 70 yrs:] HR 1.63 (95%CI; 1.08-2.48 [underlined: Male gender:] HR 0.73 (95%CI; 0.58-0.92) [underlined: Remote bleeding event:] HR 1.79 (95%CI; 1.36-2.37) [underlined: Recent bleeding event:] HR 1.85 (95%CI; 1.41-2.44) [underlined: Alcohol or drug abuse:] HR 2.03 (95%CI; 1.07-3.83) [underlined: Diabetes:] HR 1.31 (95%CI; 1.04-1.66) [underlined: Anemia:] HR 2.36 (95%CI: 1.76-3.17) [underlined: Antiplatelet drug:] HR 1.38 (95%CI 1.07-1.78) [underlined: Results from Validation Cohort] [underlined: Risk Index (Shireman 2006): (p<0.0001)] Low: 0.9% (cases=35) Moderate: 2.0% (cases=48) High: 5.4% (cases=12) [underlined: Risk Index (Kuijer 1999): (p=0.74)] Moderate: 1.5% High: 1.8% [underlined: Risk Index (OBRI): (p<0.0001)] Moderate: 1.0% High: 2.5%
Smith 2002^55^ United States Public | Case-control Cases: history of stroke, taking warfarin, and hospitalized for warfarin-related ICH; age ≥ 60 Controls: history of stroke, taking warfarin, age ≥ 60 80% of each group treated with warfarin as a result of previous stroke or TIA | N(cases): 82(26) Mean age: 75 53.% Male | Intracranial hemorrhage | [underlined: Comorbidity] [underlined: Leukoaraiosis:] OR 12.9 (95%CI;2.8-59.8); adjusted OR 8.4 (95%CI; 1.4-51.5) [underlined: Severe (grade 3 or 4) leukoaraiosis:] OR 24.9 (95%CI;4.5-137.4) vs. absence of leukoaraiosis
Stroke Prevention in Atrial Fibrillation (SPAF) Investigators 1996^48^ United States SPAF II study Public | Warfarin arm of RCT comparing warfarin and aspirin Non-valvular atrial fibrillation Candidates for warfarin anticoagulation Mean follow-up 2.6 years | N(cases): 555(34) Mean age: 70 for all patients 69% Male | Bleeding involving the central nervous system; requiring hospitalization, blood transfusion, and/or surgical intervention; or resulted in permanent functional impairment to any degree | [underlined: Univariate Risk of Bleeding During Warfarin Treatment:] * Age > 75 yr: RR 2.6 (p=0.009 Male gender: RR 0.9 Comorbidities Thromboembolism: RR 1.9 CHF: RR 2.0 (p=0.05) Diabetes: RR 1.9 (p=0.09) GI bleeding: RR 1.6 Hypertension: RR 1.1 Other Meds NSAIDs: RR 1.3 Other prescriptions: RR 1.2/drug (p=0.003) Other Tobacco Use: RR 1.9 (p=0.1) Alcohol: RR 1.0
Van Leeuwen 2008^82^ The Netherlands LAVA study Funding NR | Case-control study nested within a cohort of patients with prosthetic heart valves treated in four anticoagulation clinics between 1985-1993 Cases had a hemorrhagic event during follow-up. Controls were matched 2 per case on age and sex. | N(cases): 460(154) | Hemorrhagic events included: intracranial and spinal hemorrhage; or major extracranial hemorrhage leading to death or hospitalization (except hemorrhage that led to hospital admission for diagnostic procedures only). | INR Time in Range and Variability:^**^ In range & stable = Reference In range & unstable: OR 1.0 (0.5-2.0) Outrange & stable: OR 1.6 (0.9-3.1) Outrange & unstable: OR 2.7 (1.4-4.9)
White 1996^50^ United States - VA National Consortium of Anticoagulation Clinics Government + industry | Retrospective review of patients followed in clinics during 4/89 Prospective follow-up of all patients with life-threatening bleeding during retrospective review AND all patients between 6/90 and 4/93 Patients treated with warfarin for at least 6 weeks No restriction on indication for warfarin therapy 3,865 PY of follow-up | N(cases): 1,999(32) Mean age: 58.79 (SD=14.3) 75.3% Male | Life-threatening: cardiopulmon-ary arrest, surgical or angio-graphic intervention to stop the bleeding, irreversible sequelae (including MI, ICH, blindness, or fibrothroax), or any 2 of the following: transfusion of ≥ 3 U of blood, hypotension, critical anemia, or acute bleeding | Male gender:^*^ 21 of 32 bleeding cases (66%) vs. 75.3% of study population Primary Indication^*^ Mechanical valve: 17/32 (53%) vs. 20% of study population VTE: 5/32 (16%) vs. 23.9% of study population Atrial fibrillation: 6/32 (19%) vs. 16.9% of study population

Risk Factor categories (* = Unadjusted; **= Adjusted for Age and/or basic demographics like gender; ***=multivariable adjustment for other covariates thought to be related to serious bleeding.)

/PYr =per patient year