# SUMMARY AND DISCUSSION

Anemia commonly complicates heart disease. Despite its association with poor outcomes and a biologically plausible argument supporting anemia correction, we found little evidence that use of ESAs or blood transfusions improve health outcomes in patients with heart disease. A limited evidence base consisting mainly of one trial suggests correction of iron deficiency in patients with symptomatic heart failure improves exercise tolerance and quality of life.

By far, the largest number of trials has examined ESAs in patients with heart failure, and most of these included patients with systolic heart failure. Though a grouped analysis of these mainly small, single-center studies shows some initial promise that ESAs may improve exercise tolerance, the evidence base is limited by inconsistent findings across trials, with some finding benefit and others finding no effect. There are a number of possible reasons for the discrepant results including differences in patient populations, treatment dosing and formulation, and outcomes examined. For example, the largest of the trials19 enrolled slightly older patients and achieved a slightly smaller hemoglobin improvement with ESA use than did other trials finding a benefit. However, our analyses suggest that the clearest contributor to the discrepant findings was the quality of the individual studies themselves, with the poorer quality studies generally supporting a greater benefit from ESAs and the more rigorous trials finding a neutral effect.

Our review differs from a similar recent review of ESAs72 for three main reasons: 1) we evaluated studies in both heart failure and CHD patients, though most studies focused on heart failure; 2) we conducted additional analyses investigating the impact of study quality on the overall results; and 3) we included studies of patients with advanced kidney disease if there were separately reported data for the subgroup of patients with comorbid heart disease. We felt the latter difference was justifiable because kidney disease is common among patients with heart disease, and we felt these data were important in understanding the potential benefits and harms in this population.

Though there were few excess harms reported in the smaller ESA trials of heart failure patients, the excess risk associated with ESAs in CKD populations73 and cancer populations74 is of concern. Moreover, our own analysis suggests the potential for serious harms associated with aggressive ESA use among the large proportion of patients with heart disease and comorbid CKD. On the other hand, these data may not apply to patients with symptomatic heart failure and reduced systolic function, and they do not elucidate the role of less aggressive ESA use, leaving us with very limited evidence with which to truly evaluate the balance of benefits and harms of ESAs in patients with heart disease. While the large RED-HF trial should more definitively establish the balance of benefits and harms of ESA use in patients with heart failure, the current uncertainty of benefit and the possibility of significant harms suggest widespread use of ESAs in patients with heart disease may be premature. For patients with comorbid chronic kidney disease, the recent cautious FDA recommendations seem reasonable, as they acknowledge the uncertainty of the role of ESA use and suggest that, if they are to be used at all, patients should have Hgb of at least < 10 g/dL.75

There is good evidence from one methodologically sound, large multicenter trial that intravenous iron carboxymaltose improves exercise tolerance, quality of life, and exercise duration in patients with chronic, stable systolic heart failure.33 These results are most applicable to iron deficient patients with NYHA class III heart failure; relatively few patients with milder degrees of heart failure were included. It also may be premature to apply these results to patients with more subtle evidence of relative iron deficiency. Biologic plausibility and test of concept studies suggest iron replacement could play a role in improving symptoms of heart failure even when, theoretically, iron stores are adequate because symptoms may be related to a functional misuse of iron rather than absolute deficiency.4 Nevertheless, though the criteria used to define iron deficiency were fairly broad, most patients enrolled in the FAIR HF trial had evidence of more advanced iron deficiency and limited iron stores. Finally, though these results are encouraging and have the potential to influence treatment of heart failure, the long-term health and cost implications of this are uncertain, and harms have not been more widely assessed.

Despite a paucity of data to support this contention, for decades, many physicians adhered to the “10/30 rule,” transfusing patients with hemoglobin under 10 g/dL and hematocrit under 30 percent for perceived safety reasons.76 In recent years, the recognition of immunomodulatory effects from leukocyte contamination and changes in RBCs with storage that impair oxygen exchange have led to increased scrutiny of RBC transfusion practice, culminating in the TRICC trial. After its publication, there was widespread adoption of more restrictive transfusion standards. However, because oxygen extraction is already maximized in the coronary circulation, concern has remained that patients with fixed coronary stenoses, who cannot increase blood flow to enhance oxygen delivery, will be more susceptible to ischemia in the setting of anemia and, therefore, should generally be transfused to a higher target than the general population. Often, this continues to be a hemoglobin of 10 g/dL.

In the perioperative literature, accumulating evidence from randomized controlled trials supports use of a conservative hemoglobin trigger no higher than 8 g/dL among heart disease patients in the intra- and postoperative setting. The results of the FOCUS trial, by far the largest study to investigate transfusion use in heart disease with over 2,000 enrolled patients, have thus far been released only in abstract form, but it found no difference in mortality, ability to walk across a room unaided, falls, or readmissions with transfusion at a threshold of 8 versus 10 g/dL.69 While they have some methodological weaknesses, four randomized controlled trials in cardiac surgery, one additional study in hip fracture, and one trial in vascular surgery all were consistent in finding no difference in mortality or other health outcomes with more restrictive use of transfusion.63-68 No similar trial has been conducted in the general surgery population.

The data from observational studies in the perioperative setting are congruent with the results from randomized controlled trials. In non-cardiac surgery cohorts, transfusion did not appear to offer any protection.41, 68, 70 We chose to exclude cardiac surgery observational cohorts from our review; nevertheless, in 13 out of 14 such studies aggregated in two prior reviews, the primary results suggested increased risk of adverse clinical events, and the fourteenth was neutral.77, 78

No definitive conclusions about best transfusion practice in heart disease outside of the perioperative setting can be drawn from the evidence from randomized controlled trials. The TRICC subgroup analysis found no significant difference in survival between restrictive and liberal transfusion groups, but mortality was slightly lower in the liberally transfused group, a trend opposite of that noted in the overall population or any other studied subgroup.39 In any case, it is difficult to extrapolate from this critically ill population, where the mean APACHE II score was 23, most patients were mechanically ventilated, and many had noncardiac primary diagnoses. Meanwhile, the CRIT trial suggests that transfusion leads to heart failure exacerbations in ACS patients but was too small to properly evaluate for any effect on survival or recurrent myocardial ischemia.40 Results from the in-progress MINT trial may shed some light, but it is also small and designed only as a pilot, with the plan for a large scale follow-up trial.

Despite the limitations inherent to their design, several themes emerged in our review of the observational data that can potentially help to guide practice: 1) the evidence strongly suggests that transfusion has no benefit and may be harmful in patients with heart disease and hemoglobin > 10 g/dL; 2) outcomes do not appear to improve with transfusion in non-ST-elevation ACS patients with hemoglobin levels down to the 8 – 9 g/dL range; 3) transfusion is consistently associated with higher mortality risk in the unselected PCI population, across multiple studies with mean nadir hemoglobins of 8 – 9 g/dL; and 4) the elevated risk in the PCI population is seen in patients with anemia related or unrelated to bleeding but may be higher in the non-bleeding anemic population. There is no evidence to guide decision-making in the stable coronary disease population, and the two studies in decompensated heart failure have conflicting results.

One of the larger questions remains: at what hemoglobin threshold does transfusion become protective in ACS patients (i.e., the risks of anemia exceed the hazards of transfusion)? Wu et al. found that transfused AMI patients had lower adjusted mortality than nontransfused patients at any hemoglobin level under 10-11 g/dL,59 and Sabatine et al. noted that STEMI patients appeared to have lower cardiovascular mortality if they received PRBCs at a hemoglobin below a threshold of 12 g/dL.57 In contrast, Sabatine found increased risk of major adverse cardiac events in NSTE-ACS patients who received transfusion at any hemoglobin level; and Rao et al. found no benefit to transfusion in NSTE-ACS down to hemoglobin of ∼7 g/dL, and a substantially increased risk of death with transfusion above hemoglobin of 10 g/dL.52 One other study found a significantly reduced risk of death at six months in AMI patients transfused at hemoglobin < 8 g/dL,58 and two noted non-significant trends toward improved survival in NSTE-ACS with transfusion at a hemoglobin below 8 – 9 g/dL.54, 55 All three studies found higher adjusted mortality in patients transfused above the 8 – 9 g/dL hemoglobin threshold.

Why might the identified hemoglobin thresholds differ across studies? In particular, can we explain the outlier findings by Wu and Sabatine that transfusion may be beneficial above a hemoglobin of 10 g/dL? The patients in the Wu study were generally older than in other trials, with potentially greater comorbidities (having not been screened for a clinical trial), and had lower rates of exposure to red blood cells. In contrast to many of the other studies, the Wu study relied on claims data with limited granularity. For example, the study grouped patients according to baseline anemia and did not examine how the development of anemia during hospitalization or the timing of transfusion affected outcomes. Though they excluded patients with major bleeding, it is almost certain that mean hemoglobin fell over the course of hospitalization; thus, their results, stratified by admission hemoglobin, would seem to overestimate any potential nadir hemoglobin threshold below which transfusion may be beneficial. Wu also excluded patients who underwent CABG, and fewer patients in the Wu study had PCI or reperfusion therapy. In theory, revascularized/reperfused patients may be more tolerant of severe anemia than their conservatively managed counterparts, since they can increase myocardial oxygen delivery through augmentation of blood flow without the need for PRBCs.

The Sabatine study results suggest that STEMI patients, who suffer abrupt and complete occlusion of a coronary artery, may have a lower tolerance for anemia than NSTE-ACS patients and thus benefit more from transfusion, even to a hemoglobin of 12 g/dL. However, like Wu et al., they used admission hemoglobin in their study, so their results likely inflate the threshold hemoglobin nadir. Moreover, several other studies that included STEMI patients primarily or exclusively did not find any evidence of benefit from transfusion.50, 51, 56, 58 PCI rates were generally higher in these studies, however, which again might explain the difference.

As noted, aside from inconsistency of results, the major limitation of this body of observational studies is selection bias, namely, confounding by indication.79 In other words, because of the observational nature of these studies, the decision to transfuse patients was based on clinical judgment which, in turn, would be naturally influenced by severity of illness, symptoms, and observation of bleeding. Indeed, the studies show that the groups who were transfused more aggressively were more severely ill. Additionally, bleeding rates did vary substantially across studies but were inconsistently reported; one might reasonably expect that the risk-benefit balance of red blood cell transfusion would change in the setting of bleeding compared to stable blood volume. Despite, in some cases, the very careful propensity adjustment, the possibility of residual confounding remains and renders this a fairly tenuous evidence base.

Perhaps in part because of the conflicting results, there is continued widespread variation in RBC transfusion practices, highlighting the need for more definitive guidance from large controlled clinical trials examining the comparative benefits of liberal and conservative transfusion strategies in patients with heart disease. Of note, the CRIT trial could not enroll their goal of 92 patients in over six years of active recruitment; it is not clear why there were difficulties with recruitment, but this raises concerns about the feasibility of a large scale trial. There is increasing evidence as well that freshly collected units may be safer and more effective than PRBCs stored for longer periods;45, 80 future studies should also look specifically at the comparative benefits/risks of transfusion of fresh RBCs in the heart disease population.

## CLINICAL APPLICATIONS

Clinicians encounter anemia in many different types of patients with heart disease, and may need to understand how the overall evidence base for anemia treatment pertains to the patient in front of them. Here we summarize how the data presented previously might apply to different common clinical scenarios:

1. Outpatient with stable NYHA class III congestive heart failure, ferritin of 50 μg/dL and a Hgb of 10g/dL
  Intravenous iron supplementation could be considered to improve symptoms, but there is no consistent good-quality evidence at this time to support the use of ESAs or blood transfusions in this patient. The use of iron could even be considered if this patient had a normal hemoglobin. Of note, the data supporting IV iron comes largely from one trial, albeit a well-conducted one, that reported only short-term quality of life and exercise tolerance outcomes.33 Furthermore, the use of IV iron would be unsupported if this patient had milder heart failure symptoms or if the ferritin were normal given that there were few such patients included in the trial. Though a number of trials have examined the use of ESAs for patients similar to this, they do not convincingly show a consistent benefit and there may be important harms, especially if this patient had advanced kidney disease. A larger ongoing trial of ESA use should better clarify their role in this type of patient. There are no trials of blood transfusions applicable to this patient.
2. Outpatient with stable NYHA class III congestive heart failure, end stage renal disease on hemodialysis, and Hgb 9 g/dL
  The decision to use ESAs would be based largely on this patient's comorbid kidney disease rather than the heart disease itself. The once common practice of using ESAs to raise hemoglobin in patients with advanced chronic kidney disease has been undermined by recent large-scale trials, and new FDA recommendations suggest use of ESAs only for patients with Hgb < 10 g/dL, and with as low a dose necessary to obviate blood transfusion. Three of these trials included substantial proportions of heart disease patients and found no benefit and possible serious harms from ESAs titrated to normal or near-normal hemoglobin.13, 26, 30 The benefit of titrating ESAs to lower hemoglobin targets in patients with heart disease and advanced kidney disease remains unexplored. There are no studies of iron supplementation or blood transfusion that would apply to this patient.
3. Hospitalized patient with decompensated heart failure and Hgb 9 g/dL
  There is no data to guide the use of ESAs or iron in this patient. It is noteworthy that nearly all of the ESA and iron trials reviewed would have excluded patients like this with decompensated disease. Two observational studies of blood transfusions in patients hospitalized with CHF found conflicting results and do not convincingly support routine transfusion of patients like this, though the evidence base is very limited.
4. Patient with acute coronary syndrome and Hgb 9 g/dL
  There is very little good direct evidence to guide whether or not to administer blood transfusions in this patient. One older trial of critically ill patients with cardiovascular disease found that patients transfused more aggressively (Hgb threshold 10 g/dL) did no better than those transfused less aggressively (threshold 7 g/dL). A small recent trial suggested a more aggressive strategy may actually be harmful in patients with acute coronary syndrome. Many observational studies in patients with ACS have found conflicting results, though the majority of them suggest increased harms associated with transfusions certainly above Hgb 10g/dL and in some cases, above Hgb > 8 g/dL, especially in patients who have undergone PCI.
  No trials have evaluated iron in patients with ACS.
5. Outpatient with chronic stable angina and Hgb 8 g/dL
  There is no good evidence that directly applies to this patient. However, a large study of patients with ESRD and heart disease, many of whom had a history of angina, showed ESAs titrated to a normal hemoglobin did not reduce the incidence of angina requiring hospitalization and was associated with increased thrombotic events and higher mortality.26 Though patients in this study also received IV iron, there are no studies of IV iron alone in patients with chronic stable angina, nor are there studies examining blood transfusions.
6. Patient admitted with a hip fracture awaiting surgery who has known, stable CHD and anemia with a Hgb of 9 g/dL
  There is no evidence that transfusing such patients above a hemoglobin of 8 g/dL improves outcomes. Data from one large randomized controlled trial and a smaller pilot study found no benefit of transfusing patients to a target hemoglobin of 10 g/dL compared to 8 g/dL. There is no data which addresses the use of ESAs or iron in such patients.

## LIMITATIONS

Because our review was focused on patient-centered health outcomes, we did not include physiologic surrogates of exercise tolerance such as Vo2 max. In excluding such outcomes, we could have missed evidence of benefit on proximal outcomes. The largest ESA trials by far are those of patients with advanced renal disease and comorbid heart disease. We felt it important to include these studies given the large proportion of heart disease patients with comorbid chronic kidney disease and the potential harms these studies underscore. However, we acknowledge the limited applicability of these results to many patients with heart failure. The inclusion of observational studies in our review of the efficacy of blood transfusions may risk overstating the depth of the evidence base when, in fact, there is little trial data to guide practice and the risk of bias in the observational studies is likely too high to make them a reliable source of evidence to guide decision-making. Nevertheless, we felt the inclusion of such studies would allow greater transparency of the types of studies that are, de facto, currently guiding practice.

## FUTURE STUDIES

Ongoing studies such as RED-HF should be able to more clearly define whether or not there is a role for ESAs in the treatment of anemic heart failure patients. If the study results are positive, there may be a need for future studies comparing the relative benefits of ESAs and iron in heart failure patients. Given that most ESA studies were conducted in patients with systolic dysfunction but a large proportion of CHF patients have preserved systolic function, future studies should clarify the role of ESAs in patients with preserved systolic function. There should be more studies of anemic patients with ischemic heart disease. Future studies should better clarify the influence of chronic kidney disease on the effectiveness of various anemia treatments. Rather than the very high hemoglobin targets trials to date have examined in patients with advanced kidney disease, future studies may consider the value of more moderate hemoglobin targets given the remaining uncertainty for patients with moderate anemia. There is a pressing need for more trials examining the role of blood transfusions; treatment of patients with stable or decompensated heart failure, as well as patients with stable, asymptomatic or actively symptomatic ischemic heart disease, remains uncertain.

## CONCLUSIONS

Anemia is common in patients with heart disease, but the evidence base to date does not convincingly support a role for ESAs for anemia correction. Iron treatment may help ameliorate symptoms over the short-term in patients with symptomatic heart failure. The role of blood transfusions remains understudied and unclear. Table 5 summarizes the evidence on the effectiveness of these therapies according to patient population and outcome.

Table 5 Summary of the Evidence for the Effects of ESAs, Iron and Blood Transfusions for Anemia, by Patient Population and Outcome

Treatment | Outcome | Effect^*^ | GRADE Classification^†^ | Comment
Stable CHF, and no worse than stage 3 CKD
ESAs | Exercise tolerance and duration | (∼) | Moderate | Inconsistent results and methodologic weaknesses in some studies limit the evidence base. Overall, studies with low risk of bias found no significant effect.
ESAs | Quality of life | (∼) | Low | Infrequent reporting, inconsistent results, the variety of instruments used, and methodologic weaknesses in some studies greatly limit the evidence base.
ESAs | Mortality | (∼) | Low | Based on mainly small, single center trials with limited power and low event rates.
ESAs | Hospitalizations | (∼) | Low | Inconsistent results and methodologic weaknesses in some studies limit the evidence base. The two studies with low risk of bias found no significant effect.
ESAs | Harms including hypertension, cerebrovascular and thrombotic events | (∼) | Low | Based on mainly small, single-center trials with low event rates.
Iron | Exercise tolerance and duration | (+) | Moderate/High | One well-conducted large multicenter trial and two smaller trials found benefit.
Iron | Quality of life | (+) | Moderate/High | One well-conducted large multicenter trial and two smaller trials found benefit.
Iron | Mortality | (∼)/(+) | Low | The one large trial showed a trend towards benefit, but was, like the two smaller trials, not powered for this outcome.
Iron | Cardiovascular events | (+) | Moderate | One large multicenter trial found benefit, but follow-up was relatively short.
Iron | Serious harms | (∼) | Moderate | Based on one large and two small trials.
Blood transfusions | All outcomes | (0) | | No evidence.
Stable CHF, and stage 4 or 5 CKD
ESAs | Exercise tolerance and duration | (0) | | No evidence. Trials including subgroups of CHF patients did not report this outcome separately.
ESAs | Quality of life | (∼) | Low | One large trial of heart disease patients including large subgroup of CHF patients, but subgroup specific data not available.
ESAs | Mortality | (-) | Moderate | Based on two large trials including large numbers with CHF; in one trial the increased risk of mortality was not significant; type and severity of CHF not reported.
ESAs | Cardiovascular events | (∼) | High | Based on three large trials including large numbers with CHF; type and severity of CHF not reported.
ESAs | Venous thrombosis | (-) | Moderate | Based on two large trials including large numbers with CHF; type and severity of CHF not reported; effects of more moderate hemoglobin targets not tested.
ESAs | Hypertension, cerebrovascular events | (−) | Low | Based on one large trial including large numbers with CHF, but CHF subgroup data not separately reported for this outcome.
Iron | All outcomes | (0) | | No evidence.
Blood transfusions | All outcomes | (0) | | No evidence.
Decompensated CHF
ESAs | All outcomes | (0) | | No evidence.
Iron | All outcomes | (0) | | No evidence.
Blood transfusions | Mortality | (−) | Very low | Two observational studies found conflicting results – one showed harm, one a possible benefit.
Stable CHD
ESAs | Mortality | (−) | Low | One large trial of heart disease patients including large subgroup of CHD patients, but subgroup specific data not available. Patients with ESRD, unclear application to other populations.
ESAs | Quality of life | (∼) | Low | One large trial of heart disease patients including large subgroup of CHD patients, but subgroup specific data not available. Patients with ESRD, unclear application to other populations.
ESAs | Venous thrombosis | (−) | Low | One large trial of heart disease patients including large subgroup of CHD patients, but subgroup specific data not available. Patients with ESRD, unclear application to other populations.
ESAs | All other outcomes | (0) | | No evidence.
Iron | All outcomes | (0) | | No evidence.
Blood transfusions | All outcomes | (0) | | No evidence.
Acute coronary syndrome
ESAs | All outcomes | (0) | | No evidence.
Iron | All outcomes | (0) | | No evidence.
Blood transfusions | Mortality | (∼) | Moderate | Two RCTs, one with limited applicability to non ICU population, showed no benefit from transfusing above Hgb > 10 g/dL. Observational studies in PCI patients consistently showed no benefit and possible harm.
Blood transfusions | Cardiovascular events | (∼) | Low | Two RCTs found conflicting results: one found harm, a larger trial found no effect. Observational studies did not commonly report this as a separate outcome.
Non-cardiac surgery
ESAs | All outcomes | (0) | | No evidence.
Iron | All outcomes | (0) | | No evidence.
Blood transfusions | Mortality | (∼) | Low | One large RCT, but reported only in abstract form and only applicable to hip fracture patients.
Cardiac surgery
ESAs | All outcomes | (0) | | No evidence.
Iron | All outcomes | (0) | | No evidence.
Blood transfusions | Mortality | (∼) | Moderate | Two large and two small RCTs with some methodologic weaknesses.

GRADE = Grades of Recommendation, Assessment, Development, and Evaluation; ICU = intensive care unit; RCT = randomized controlled trial.

* Effect: (+) benefit; (−) harm; (∼) mixed findings/no effect; (0) no evidence.

† GRADE classification: high = further research is very unlikely to change our confidence on the estimate of effect; moderate = further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate; low = further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate; very low = any estimate of effect is very uncertain.