# REFERENCES

1 Boyd CM, Leff B, Wolff JL, et al. Informing clinical practice guideline development and implementation: prevalence of coexisting conditions among adults with coronary heart disease. Journal of the American Geriatrics Society. May. 2011;59(5):797-805. [pmid: 21568950].
2 Felker GM, Adams KF Jr, Gattis WA, O'Connor CM. Anemia as a risk factor and therapeutic target in heart failure. Journal of the American College of Cardiology. Sep. 1. 2004;44(5):959-966. [pmid: 15337204].
3 Malyszko J, Bachorzewska-Gajewska H, Levin-Iaina N, et al. Prevalence of chronic kidney disease and anemia in patients with coronary artery disease with normal serum creatinine undergoing percutaneous coronary interventions: relation to New York Heart Association class. Israel Medical Association Journal: Imaj. Aug. 2010;12(8):489-493.
4 Gonzalez-Costello J, Comin-Colet J. Iron deficiency and anaemia in heart failure: understanding the FAIR-HF trial. European Journal of Heart Failure. Nov. 2010;12(11):1159-1162. [pmid: 20855375].
5 Komajda M, Anker SD, Charlesworth A, et al. The impact of new onset anaemia on morbidity and mortality in chronic heart failure: results from COMET. European Heart Journal. Jun. 2006;27(12):1440-1446. [pmid: 16717081].
6 Kosiborod M, Smith GL, Radford MJ, Foody JM, Krumholz HM. The prognostic importance of anemia in patients with heart failure. American Journal of Medicine. Feb. 1. 2003;114(2):112-119. [pmid: 12586230].
7 Silverberg DS, Wexler D, Blum M, et al. The use of subcutaneous erythropoietin and intravenous iron for the treatment of the anemia of severe, resistant congestive heart failure improves cardiac and renal function and functional cardiac class, and markedly reduces hospitalizations. Journal of the American College of Cardiology. Jun. 2000;35(7):1737-1744. [pmid: 10841219].
8 Higgins JPT, Altman DG, editors. Chapter 8: Assessing risk of bias in included studies. Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions. 2008. Version 5.0.1. The Cochrane Collaboration. 2008. Availablefrom www.cochrane-handbook.org.
9 Atkins D, Best D, Briss PA, et al. Grading quality of evidence and strength of recommendations. BMJ. Jun. 19. 2004;328(7454):1490. [pmid: 15205295].
10 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-188. [pmid: 3802833].
11 Egger M, Davey Smith G, Schneider M, Minder C. Bias in meta-analysis detected by a simple, graphical test. BMJ. Sep. 13. 1997;315(7109):629-634. [pmid: 9310563].
12 Comin-Colet J, Ruiz S, Cladellas M, Rizzo M, Torres A, Bruguera J. A pilot evaluation of the long-term effect of combined therapy with intravenous iron sucrose and erythropoietin in elderly patients with advanced chronic heart failure and cardio-renal anemia syndrome: influence on neurohormonal activation and clinical outcomes. Journal of Cardiac Failure. Nov. 2009;15(9):727-735. [pmid: 19879457].
13 Szczech LA, Barnhart HX, Sapp S, et al. A secondary analysis of the CHOIR trial shows that comorbid conditions differentially affect outcomes during anemia treatment. Kidney International. Feb. 2010;77(3):239-246. [pmid: 19890274].
14 Pfeffer MA, Burdmann EA, Chen CY, et al. Baseline characteristics in the Trial to Reduce Cardiovascular Events With Aranesp Therapy (TREAT). American Journal of Kidney Diseases. Jul. 2009;54(1):59-69. [pmid: 19501439].
15 Palazzuoli A, Silverberg DS, Calabr, et al. Beta-erythropoietin effects on ventricular remodeling, left and right systolic function, pulmonary pressure, and hospitalizations in patients affected with heart failure and anemia. Journal of Cardiovascular Pharmacology. Jun. 2009;53(6):462-467. [pmid: 19455052].
16 Parissis JT, Kourea K, Andreadou I, et al. Effects of Darbepoetin Alfa on plasma mediators of oxidative and nitrosative stress in anemic patients with chronic heart failure secondary to ischemic or idiopathic dilated cardiomyopathy. American Journal of Cardiology. Apr. 15. 2009;103(8):1134-1138. [pmid: 19361602].
17 Kourea K, Parissis JT, Farmakis D, et al. Effects of darbepoetin-alpha on quality of life and emotional stress in anemic patients with chronic heart failure. European Journal of Cardiovascular Prevention & Rehabilitation. Jun. 2008;15(3):365-369. [pmid: 18525396].
18 Parissis JT, Kourea K, Panou F, et al. Effects of darbepoetin alpha on right and left ventricular systolic and diastolic function in anemic patients with chronic heart failure secondary to ischemic or idiopathic dilated cardiomyopathy. American Heart Journal. Apr. 2008;155(4):751.e751-757. [pmid: 18371487].
19 Ghali JK, Anand IS, Abraham WT, et al. Randomized double-blind trial of darbepoetin alfa in patients with symptomatic heart failure and anemia. Circulation. Jan. 29. 2008;117(4):526-535. [pmid: 18195176].
20 Besarab A, Goodkin DA, Nissenson AR, Normal Hematocrit Cardiac Trial A. The normal hematocrit study--follow-up. New England Journal of Medicine. Jan. 24. 2008;358(4):433-434. [pmid: 18216370].
21 Palazzuoli A, Silverberg DS, Iovine F, et al. Effects of beta-erythropoietin treatment on left ventricular remodeling, systolic function, and B-type natriuretic peptide levels in patients with the cardiorenal anemia syndrome. American Heart Journal. Oct. 2007;154(4):645.e649-615. [pmid: 17892986].
22 van Veldhuisen DJ, Dickstein K, Cohen-Solal A, et al. Randomized, double-blind, placebo-controlled study to evaluate the effect of two dosing regimens of darbepoetin alfa in patients with heart failure and anaemia. European Heart Journal. Sep. 2007;28(18):2208-2216. [pmid: 17681958].
23 Ponikowski P, Anker SD, Szachniewicz J, et al. Effect of darbepoetin alfa on exercise tolerance in anemic patients with symptomatic chronic heart failure: a randomized, double-blind, placebo-controlled trial. Journal of the American College of Cardiology. Feb. 20. 2007;49(7):753-762. [pmid: 17306703].
24 Mancini DM, Kunavarapu C. Effect of erythropoietin on exercise capacity in anemic patients with advanced heart failure. Kidney International - Supplement. Nov. 2003;(87):S48-52. [pmid: 14531773].
25 Silverberg DS, Wexler D, Sheps D, et al. The effect of correction of mild anemia in severe, resistant congestive heart failure using subcutaneous erythropoietin and intravenous iron: a randomized controlled study. Journal of the American College of Cardiology. Jun. 1. 2001;37(7):1775-1780. [pmid: 11401110].
26 Besarab A, Bolton WK, Browne JK, et al. The effects of normal as compared with low hematocrit values in patients with cardiac disease who are receiving hemodialysis and epoetin. New England Journal of Medicine. Aug. 27. 1998;339(9):584-590. [pmid: 9718377].
27 Bellinghieri G, Savica V, De Gregorio C, De Gregorio G. Use of erythropoietin in ischemic and arrhythmic cardiopathy of hemodialyzed patients. Contributions to Nephrology. 1994;106:135-137. [pmid: 8174359].
28 Palazzuoli A, Silverberg D, Iovine F, et al. Erythropoietin improves anemia exercise tolerance and renal function and reduces B-type natriuretic peptide and hospitalization in patients with heart failure and anemia. American Heart Journal. Dec. 2006;152(6):1096. e1099-1015. [pmid: 17161060].
29 Desai A, Lewis E, Solomon S, McMurray JJV, Pfeffer M. Impact of erythropoiesis-stimulating agents on morbidity and mortality in patients with heart failure: An updated, post-TREAT meta-analysis. European Journal of Heart Failure. 2010;12(9):936-942. [pmid: 20525985].
30 Pfeffer MA, Burdmann EA, Chen CY, et al. A trial of darbepoetin alfa in type 2 diabetes and chronic kidney disease. New England Journal of Medicine. Nov. 19. 2009;361(21):2019-2032. [pmid: 19880844].
31 Amgen. RED-HF™ Trial - Reduction of Events With Darbepoetin Alfa in Heart Failure Trial. ClinicalTrials.gov identifier: NCT00358215. Ongoing study.
32 Maurer MS. Anemia in Heart Failure With a Preserved Ejection Fraction (HFPEF). ClinicalTrials.gov Identifier: NCT00286182. Ongoing study.
33 Anker SD, Comin Colet J, Filippatos G, et al. Ferric carboxymaltose in patients with heart failure and iron deficiency. New England Journal of Medicine. Dec. 17. 2009;361(25):2436-2448. [pmid: 19920054].
34 Toblli JE, Lombraña A, Duarte P, Di Gennaro F. Intravenous iron reduces NT-pro-brain natriuretic peptide in anemic patients with chronic heart failure and renal insufficiency. Journal of the American College of Cardiology. Oct. 23. 2007;50(17):1657-1665. [pmid: 17950147].
35 Okonko DO, Grzeslo A, Witkowski T, et al. Effect of intravenous iron sucrose on exercise tolerance in anemic and nonanemic patients with symptomatic chronic heart failure and iron deficiency FERRIC-HF: a randomized, controlled, observer-blinded trial. Journal of the American College of Cardiology. Jan. 15. 2008;51(2):103-112. [pmid: 18191732].
36 Maluenda G, Lemesle G, Ben-Dor I, et al. Value of blood transfusion in patients with a blood hematocrit of 24% to 30% after percutaneous coronary intervention. American Journal of Cardiology. Oct. 15. 2009;104(8):1069-1073. [pmid: 19801026].
37 Maluenda G, Lemesle G, Syed A, et al. Does transfusion for major bleeding after percutaneous coronary intervention impact clinical outcome in patients admitted with normal Hematocrit?. Journal of the American College of Cardiology. 2009;53(10):A72.
38 Maluenda G, Lemesle G, Syed A, et al. Should patients who develop anemia (hematocrit (less-than or equal to) 27%) after percutaneous coronary intervention be transfused?. Journal of the American College of Cardiology. 2009;53(10):A84.
39 Hebert PC, Yetisir E, Martin C, et al. Is a low transfusion threshold safe in critically ill patients with cardiovascular diseases?. Critical Care Medicine. Feb. 2001;29(2):227-234. [pmid: 11246298].
40 Cooper HA, Rao SV, Greenberg MD, et al. Conservative Versus Liberal Red Cell Transfusion in Acute Myocardial Infarction (the CRIT Randomized Pilot Study). The American journal of cardiology. 2011.
41 Bursi F, Barbieri A, Politi L, et al. Perioperative red blood cell transfusion and outcome in stable patients after elective major vascular surgery. European Journal of Vascular & Endovascular Surgery. Mar. 2009;37(3):311-318. [pmid: 19111480].
42 Hebert PC, Wells G, Blajchman MA, et al. A multicenter, randomized, controlled clinical trial of transfusion requirements in critical care. Transfusion Requirements in Critical Care Investigators, Canadian Critical Care Trials Group. New England Journal of Medicine. Feb. 11. 1999;340(6):409-417. [pmid: 9971864].
43 Carson JL. Myocardial Ischemia and Transfusion (MINT). ClinicalTrials.gov identifier: NCT01167582. Ongoing study.
44 Kinnaird TD, Stabile E, Mintz GS, et al. Incidence, predictors, and prognostic implications of bleeding and blood transfusion following percutaneous coronary interventions. American Journal of Cardiology. Oct. 15. 2003;92(8):930-935. [pmid: 14556868].
45 Kim P, Dixon S, Eisenbrey AB, O'Malley B, Boura J, O'Neill W. Impact of acute blood loss anemia and red blood cell transfusion on mortality after percutaneous coronary intervention. Clinical Cardiology. Oct. 2007;30(10 Suppl 2):II35-43. [pmid: 18228650].
46 Yatskar L, Selzer F, Feit F, et al. Access site hematoma requiring blood transfusion predicts mortality in patients undergoing percutaneous coronary intervention: data from the National Heart, Lung, and Blood Institute Dynamic Registry. Catheter Cardiovasc Interv. Jun. 1. 2007;69(7):961-966. [pmid: 17421023].
47 Doyle BJ, Ting HH, Bell MR, et al. Major femoral bleeding complications after percutaneous coronary intervention: incidence, predictors, and impact on long-term survival among 17,901 patients treated at the Mayo Clinic from 1994 to 2005. Jacc: Cardiovascular Interventions. Apr. 2008;1(2):202-209. [pmid: 19463301].
48 Chase AJ, Fretz EB, Warburton WP, et al. Association of the arterial access site at angioplasty with transfusion and mortality: the M.O.R.T.A.L study (Mortality benefit Of Reduced Transfusion after percutaneous coronary intervention via the Arm or Leg). Heart. Aug. 2008;94(8):1019-1025. [pmid: 18332059].
49 Jani SM, Smith DE, Share D, et al. Blood transfusion and in-hospital outcomes in anemic patients with myocardial infarction undergoing percutaneous coronary intervention. Clinical Cardiology. Oct. 2007;30(10 Suppl 2):II49-56. [pmid: 18228652].
50 Jolicoeur EM, O'Neill WW, Hellkamp A, et al. Transfusion and mortality in patients with ST-segment elevation myocardial infarction treated with primary percutaneous coronary intervention. European Heart Journal. Nov. 2009;30(21):2575-2583. [pmid: 19596659].
51 Nikolsky E, Mehran R, Sadeghi HM, et al. Prognostic impact of blood transfusion after primary angioplasty for acute myocardial infarction: analysis from the CADILLAC (Controlled Abciximab and Device Investigation to Lower Late Angioplasty Complications) Trial. Jacc: Cardiovascular Interventions. Jul. 2009;2(7):624-632. [pmid: 19628185].
52 Rao SV, Jollis JG, Harrington RA, et al. Relationship of blood transfusion and clinical outcomes in patients with acute coronary syndromes. Journal of the American Medical Association. 2004;292(13):1555-1562. [pmid: 15467057].
53 Yang X, Alexander KP, Chen AY, et al. The implications of blood transfusions for patients with non-ST-segment elevation acute coronary syndromes: results from the CRUSADE National Quality Improvement Initiative. Journal of the American College of Cardiology. Oct. 18. 2005;46(8):1490-1495. [pmid: 16226173].
54 Singla I, Zahid M, Good CB, Macioce A, Sonel AF. Impact of blood transfusions in patients presenting with anemia and suspected acute coronary syndrome. American Journal of Cardiology. Apr. 15. 2007;99(8):1119-1121. [pmid: 17437739].
55 Alexander KP, Chen AY, Wang TY, et al. Transfusion practice and outcomes in non-ST-segment elevation acute coronary syndromes. American Heart Journal. Jun. 2008;155(6):1047-1053. [pmid: 18513518].
56 Shishehbor MH, Madhwal S, Rajagopal V, et al. Impact of blood transfusion on short-and long-term mortality in patients with ST-segment elevation myocardial infarction. Jacc: Cardiovascular Interventions. Jan. 2009;2(1):46-53. [pmid: 19463397].
57 Sabatine MS, Morrow DA, Giugliano RP, et al. Association of hemoglobin levels with clinical outcomes in acute coronary syndromes. Circulation. Apr. 26. 2005;111(16):2042-2049. [pmid: 15824203].
58 Aronson D, Dann EJ, Bonstein L, et al. Impact of red blood cell transfusion on clinical outcomes in patients with acute myocardial infarction. American Journal of Cardiology. Jul. 15. 2008;102(2):115-119. [pmid: 18602505].
59 Wu WC, Rathore SS, Wang Y, Radford MJ, Krumholz HM. Blood transfusion in elderly patients with acute myocardial infarction. New England Journal of Medicine. 2001;345(17):1230-1236. [pmid: 11680442].
60 Aggarwal C, Panza JA, Cooper HA, Aggarwal C, Panza JA, Cooper HA. Does the relation between red blood cell transfusion and mortality vary according to transfusion indication? A case-control study among patients with acute coronary syndromes. Coron Artery Dis. May. 2011;22(3):194-198. [pmid: 21169814].
61 Garty M, Cohen E, Zuchenko A, et al. Blood transfusion for acute decompensated heart failure--friend or foe?. American Heart Journal. Oct. 2009;158(4):653-658. [pmid: 19781427].
62 Kao DP, Kreso E, Fonarow GC, et al. Characteristics and outcomes among heart failure patients with anemia and renal insufficiency with and without blood transfusions (public discharge data from California 2000-2006). American Journal of Cardiology. Jan. 2011;107(1):69-73. [pmid: 21146689].
63 Weisel RD, Charlesworth DC, Mickleborough LL, et al. Limitations of blood conservation. Journal of Thoracic & Cardiovascular Surgery. Jul. 1984;88(1):26-38. [pmid: 6376959].
64 Johnson RG, Thurer RL, Kruskall MS, et al. Comparison of two transfusion strategies after elective operations for myocardial revascularization. Journal of Thoracic & Cardiovascular Surgery. Aug. 1992;104(2):307-314. [pmid: 1495291].
65 Bracey AW, Radovancevic R, Riggs SA, et al. Lowering the hemoglobin threshold for transfusion in coronary artery bypass procedures: effect on patient outcome. Transfusion. Oct. 1999;39(10):1070-1077. [pmid: 10532600].
66 Hajjar LA, Vincent JL, Galas FR, et al. Transfusion requirements after cardiac surgery: the TRACS randomized controlled trial. JAMA. Oct. 13. 2010;304(14):1559-1567. [pmid: 20940381].
67 Bush RL, Pevec WC, Holcroft JW. A prospective, randomized trial limiting perioperative red blood cell transfusions in vascular patients. American Journal of Surgery. Aug. 1997;174(2):143-148. [pmid: 9293831].
68 Carson JL, Terrin ML, Barton FB, et al. A pilot randomized trial comparing symptomatic vs. hemoglobin-level-driven red blood cell transfusions following hip fracture. Transfusion. Jun. 1998;38(6):522-529. [pmid: 9661685].
69 Carson JL, Terrin ML, Magaziner J, Sanders D, Cook DR, Hildebrand K. Transfusion trigger trial for functional outcomes in cardiovascular patients undergoing surgical hip fracture repair (FOCUS): The principal results. Blood. 2009;114(22).
70 Glance LG, Dick AW, Mukamel DB, et al. Association between intraoperative blood transfusion and mortality and morbidity in patients undergoing noncardiac surgery. Anesthesiology. Feb. 2011;114(2):283-292. [pmid: 21239971].
71 Hebert PC, Wells G, Tweeddale M, et al. Does transfusion practice affect mortality in critically ill patients? Transfusion Requirements in Critical Care (TRICC) Investigators and the Canadian Critical Care Trials Group. Am J Respir Crit Care Med. May. 1997;155(5):1618-1623. [pmid: 9154866].
72 Ngo K, Kotecha D, Walters JA, et al. Erythropoiesis-stimulating agents for anaemia in chronic heart failure patients. Cochrane Database of Systematic Reviews. 2010;(1):CD007613. [pmid: 20091643].
73 Palmer SC, Navaneethan SD, Craig JC, et al. Meta-analysis: erythropoiesis-stimulating agents in patients with chronic kidney disease. Annals of Internal Medicine. Jul. 6. 2010;153(1):23-33. [pmid: 20439566].
74 Agency for Healthcare Research and Quality. Comparative Effectiveness of Epoetin and Darbepoetin for Managing Anemia in Patients Undergoing Cancer Treatment - Update DRAFT. AHRQ Comparative Effectiveness Review. In progress.
75 U.S. Food and Drug Administration. FDA Drug Safety Communication: Modified dosing recommendations to improve the safe use of Erythropoiesis-Stimulating Agents (ESAs) in chronic kidney disease. 7/29/2011. at http://www.fda.gov/Drugs/DrugSafety/ucm259639.htm#.TjNK6A-AqfM.email.
76 Wang JK, Klein HG. Red blood cell transfusion in the treatment and management of anaemia: the search for the elusive transfusion trigger. Vox Sanguinis. Jan. 2010;98(1):2-11. [pmid: 19682346].
77 Gerber DR. Transfusion of packed red blood cells in patients with ischemic heart disease. Critical Care Medicine. Apr. 2008;36(4):1068-1074. [pmid: 18379229].
78 Marik PE, Corwin HL. Efficacy of red blood cell transfusion in the critically ill: a systematic review of the literature. Critical Care Medicine. Sep. 2008;36(9):2667-2674. [pmid: 18679112].
79 Norris S, Atkins D, Bruening W, et al. Selecting observational studies for comparing medical interventions. Agency for Healthcare Research and Quality. Methods Guide for Comparative Effectiveness Reviews. Rockville, MD. Available at: http://www.effectivehealthcare.ahrq.gov/ehc/products/196/454/MethodsGuideNorris_06042010.pdf. 2010.
80 Robinson SD, Janssen C, Fretz EB, et al. Red blood cell storage duration and mortality in patients undergoing percutaneous coronary intervention. American Heart Journal. May. 2010;159(5):876-881. [pmid: 20435199].
81 Carson JL, Duff A, Berlin JA, et al. Perioperative blood transfusion and postoperative mortality. JAMA. Jan. 21. 1998;279(3):199-205. [pmid: 9438739].