# METHODS

## TOPIC DEVELOPMENT

The review was commissioned by the Department of Veterans Affairs' Evidence-based Synthesis Program. We conferred with VA and non-VA experts to select the patients and subgroups, interventions, outcomes, and setting addressed in the review. We addressed the following key questions in our review of the literature:

In patients with CHF or CHD,

Key Question 1 What are the health outcome benefits and harms of treating anemia with erythropoiesis-stimulating agents (ESAs)?
Key Question #2 What are the health outcome benefits and harms of using iron to treat iron deficiency with or without anemia?
Key Question #3 What are the health outcome benefits and harms of treating anemia with red blood cell transfusions?

The criteria for patient population, treatment and comparator interventions, outcomes of interest, and patient care setting are outlined below:

Patients: Adult patients with symptomatic CHF (with or without reduced systolic function) or CHD (acute coronary syndrome, post-acute coronary syndrome, history of MI or angina, ) and anemia or iron deficiency.

Interventions:

- ESAs with or without iron: These include erythropoietin and darbepoeitin
- Iron: Intravenous or oral
- Red blood cell transfusion

Comparator: Usual care, placebo

Outcomes: Mortality (all-cause and disease specific), hospitalization (all-cause and disease-specific), exercise tolerance or duration (any metric, most commonly NYHA class, 6-minute walk test), quality of life, cardiovascular events (myocardial infarction, heart failure exacerbation, need for revascularization)

Setting: Inpatient or outpatient

Figure 1 illustrates the analytic framework that guided our review and synthesis.

Figure 1 Analytic Framework

## SEARCH STRATEGY

We conducted a search in Medline^®^ and the Cochrane database of systematic reviews of literature published from 1947 to November 2010. Appendix A provides the search strategy in detail. We obtained additional articles from systematic reviews, reference lists of pertinent studies, reviews, editorials, and by consulting experts. We also searched for information about unpublished studies on ClinicalTrials.gov. All citations were imported into an electronic database (EndNote X1).

## STUDY SELECTION

Three reviewers assessed for relevance the abstracts of citations identified from literature searches. Two reviewers independently assessed for inclusion full-text articles of potentially relevant abstracts based on the eligibility criteria shown in Appendix B. Disagreements were resolved through a consensus process.

Eligible articles had English-language abstracts and provided primary data relevant to the key questions. We included studies of anemic patients (hemoglobin < 13 g/dL in men, < 12 g/dL in women) with symptomatic CHF (with or without reduced systolic function), CHD (acute coronary syndrome, post-acute coronary syndrome, history of MI or angina), or both. Further eligibility criteria varied depending on the question of interest, as described below.

To evaluate the efficacy of ESAs, we considered prospective, controlled clinical trials of ESAs compared either to placebo or to less intensive ESA use in patients with anemia and heart disease. In evaluating the efficacy of iron, we included studies with mixed populations of anemic and non-anemic patients, but then described how treatment effects might differ for anemic and non-anemic patients. We did include studies of broader patient populations as long as they separately reported outcomes data for the subpopulation of patients with heart disease.

Included studies had to report at least one prespecified patient-centered health outcome which we defined as clinically important outcomes apparent to the patient (Appendix B). We excluded studies reporting only intermediate physiologic outcomes such as change in ejection fraction or oxygen delivery metrics.

Based on an initial exploratory search of red blood cell transfusions in patients with heart disease, we recognized there was a dearth of controlled clinical trial data and that current recommendations for blood transfusion use in heart disease patients are largely based on interpretation of observational studies. Therefore, to better understand the evidence currently guiding clinical practice, we included observational studies as well as controlled clinical trials that reported at least one of the above listed health outcomes. Given the complex technique of cardiac surgery, involving induction of hypothermia, cardioplegia, and establishment of an extracorporeal circuit, we felt that the potential confounding factors were too vast to permit use of observational data to guide decision-making. Therefore, for this population, we elected to consider controlled trials only.

To evaluate the harms of ESAs, iron, and blood transfusion, we collected adverse events data from all the included trials, and we specifically gathered data on the following events from each trial: hypertension, venous thromboembolic events (including deep venous thrombosis, pulmonary embolism, and vascular access thrombosis), and ischemic cerebrovascular events.

## DATA ABSTRACTION

From each study, we abstracted the following: study design, objectives, setting, population characteristics (including sex, age, left ventricular ejection fraction, baseline NYHA class, definition of CHD), subject eligibility and exclusion criteria, number of subjects, years of enrollment, duration of follow-up, the study and comparator interventions (including route and dosage), important co-interventions (i.e., iron administration in ESA studies), baseline hemoglobin, change in hemoglobin, health outcomes, and adverse events.

## STUDY QUALITY

Two reviewers independently assessed the quality of each trial using a tool developed by the Cochrane Collaboration.8 Disagreements were resolved through discussion. This tool asks the following questions about the methodologic characteristics of each study to guide assessment of the risk of bias:

- Was the allocation sequence adequately generated?
- Was allocation adequately concealed?
- Blinding of participants, personnel and outcome assessors: Was knowledge of the allocated intervention adequately prevented during the study?
- Were incomplete outcome data adequately addressed?
- Are reports of the study free of suggestion of selective outcome reporting?
- Was the study apparently free of other problems that could put it at a high risk of bias? (We assessed whether or not there were extreme baseline differences between groups.)

Each study was then given an overall summary assessment of either low, high, or unclear risk of bias. The risk of bias within a given study can vary according to outcome. For instance, the risk of bias associated with lack of blinding might be low for mortality outcomes, but high for more subjective outcomes such as quality of life or symptom scores.

Though there is no widely accepted standard for quality assessment of observational studies, we used the following questions to guide a comparison of observational study methodologic characteristics:

1. Was the selection of patients for inclusion unbiased? (Was any group of patients systematically excluded?)
2. Was there important differential loss to follow-up or overall high loss to follow-up? (Numbers should be given for each group.)
3. Were the events investigated specified and defined?
4. Was there a clear description of the techniques used to identify the events?
5. Was there unbiased and accurate ascertainment of events (that is, by independent ascertainers using a validated ascertainment technique)?
6. Were potential confounding variables and risk factors identified and examined using acceptable statistical techniques?
7. Was the duration of follow-up reasonable for investigated events?

Within question 6, we specifically assessed whether each study: 1) conducted an analysis adjusting for patient propensity to receive a blood transfusion, 2) accounted for bleeding complications – whether procedurally related or not – in the study population, and 3) accounted for the timing of transfusion given the potential for issues such as survival bias in which patients who died could not have received a transfusion.

We do not report an overall summary assessment for observational studies because there are no validated criteria for doing so and all would be poorly valid in determining the health outcome effects of blood transfusions.

Appendix C provides the details of our quality assessment of trials and observational studies.

## RATING THE BODY OF EVIDENCE

We assessed the overall quality of evidence for outcomes using a method developed by the GRADE Working Group.9 The GRADE method considers the consistency, coherence, and applicability of a body of evidence, as well as the internal validity of individual studies, to classify the grade of evidence across outcomes as follows:

- High = Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.
- Very Low = Any estimate of effect is very uncertain.

## DATA SYNTHESIS

We performed meta-analyses of ESA trials for each of the following outcomes: mean difference in the change of NYHA class, exercise duration during the six-minute walk test, all-cause mortality, hospitalizations, cardiovascular events, hypertension events, and ischemic cerebrovascular events. We abstracted the number of events and total subjects from each treatment arm, and obtained a pooled estimate of relative risk (RR) using a random effects model.10 We did not meta-analyze quality of life outcomes because we felt a quantitative summary estimate of effect would be less meaningful than a descriptive approach given the variety of assessment tools used.

In order to determine the influence study quality may have had on summary results, we ran analyses for all outcomes excluding those studies with high or unclear risk of bias. To determine whether the effects of ESAs were modified by anemia characteristics, we conducted analyses according to baseline hemoglobin and mean change in hemoglobin in the intervention group, using 11g/dL and 2 g/dL, respectively, as the cutpoints based on distribution of values among included studies. If only the hematocrit was reported, we used a conversion of 3:1 to approximate the hemoglobin value.

Statistical heterogeneity was assessed by Cochran's Q test and I^2^ statistic.8 Because of the small number of trials that could be combined, we did not perform assessments for publication bias.11 All analyses were performed using Stata 10.0 (StataCorp, College Station, TX, 2007).

Because there were only three trials examining the effects of iron therapy, with one large trial dominating results, we decided to only qualitatively synthesize these results. We also qualitatively synthesized the mostly observational blood transfusion literature.

## PEER REVIEW

A draft version of this report was sent to the technical expert panel and additional peer reviewers. The comments and suggestions we received from reviewers and our responses in revising the report are provided in Appendix D.