# QUALITY ASSESSMENT TABLES

Appendix C, Table 1 Assessment of methodologic characteristics and risk of bias in randomized controlled trials of ESA therapy in patients with CHF or CHD

Study ID | Was the allocation sequence adequately generated? | Was allocation adequately concealed? | Blinding of participants, personnel and outcome assessors: Was knowledge of the allocated intervention adequately prevented? | Were incomplete outcome data adequately addressed? | Selective outcome reporting: Are reports of the study free of suggestion of selective outcome reporting? | Other sources of bias: Was the study apparently free of other problems that could put it at a high risk of bias? | Summary assessment: risk of bias (Low, Unclear, High)
Bellinghieri, 1994^27^ | Unclear | Unclear | No | No | Unclear | No serious baseline imbalances. Randomized, but very little baseline characteristics presented though the baseline gender imbalance raises concerns that groups may not have been equal at baseline. | Overall: high risk of bias
Besarab 1998^26^ | Unclear | Unclear | Yes - low risk of bias for mortality outcome, probably low risk of bias for hospitalization, MI outcomes. High risk of bias for physical function outcome given that blinding of participants and outcome assessors is unlikely to have occurred | Low risk of bias - data for all patients enrolled is reported and an intention to treat analysis was done | It is unclear why a composite outcome was chosen. Functional status data were incompletely reported (no comparative data, only that functional status increased with increasing Hct levels) – -> high risk of bias for functional status outcomes, but probably low risk of bias for mortality outcome | No serious baseline imbalances between groups. | Overall: low risk of bias
Comin-Colet, 2009^12^ | No - high risk of bias - allocation by preference of the participant. Because preference for treatment could be associated with unmeasured confounders such as better self-management skills etc, this is a significant methodologic limitation which threatens the validity of the results. | No | No - high risk of bias for subjective outcomes | Yes | Unclear | No serious baseline imbalances between groups | Overall: high risk of bias
Ghali, 2008^19^ | Yes | Yes | Yes | Yes | Unclear | No serious baseline imbalances between groups | Overall: low risk of bias
Kourea, 2008^17^ | Unclear | Unclear | Yes - though single blind, it was placebo controlled and evaluation of QOL and depression surveys was done by blinded personnel | Yes | Unclear | No serious baseline imbalances between groups | Overall: Unclear risk of bias
Mancini, 2003^24^ | Unclear | Unclear | Personnel and outcome assessors were not blinded High risk of bias especially for QOL outcomes | Yes, though no ITT done, only 3 patients did not complete treatment | No - high risk of bias - no protocol available. The QOL outcome is not completely reported - no actual values, only that × % “improved” and the definition of improvement is not provided. | No serious baseline imbalances between groups | Overall: high risk of bias
Palazzuoli, 2006^28^ | Unclear | Unclear | Yes | Yes | Unclear | No serious baseline imbalances between groups. It is unclear if there is any overlap between patients in this study and Palazzuoli 2009 - if so, then possible multiple publication bias | Overall: Unclear risk of bias, but duplicates Palazzuoli 2007 results
Palazzuoli, 2007^21^ | Unclear | Unclear | No (for 12 month outcomes) - high risk of bias for 12 month outcomes such as NYHA class. Blinding stopped after 4 month mark. | No - high risk of bias. Not clear that ITT done. Nowhere in the results is the denominator actually reported so it is unclear what the final n was used to calculate results. | No - no protocol available. The study includes 12 month NYHA scores as an outcome, but there are no objective measures of exercise duration which one might expect as another secondary outcome measure. | No serious baseline imbalances between groups. It is unclear if there is any overlap between patients in this study and Palazzuoli 2009 – if so, then possible multiple publication bias | Overall: high risk of bias. Duplicates Palazzuoli 2006 results with some additions.
Palazzuoli, 2009^15^ | Unclear | Unclear | Blinding of personnel and outcome assessors is unclear past the 4 month mark after which intervention drug was continued, but the control group saline injections were discontinued. This could create high risk of bias for outcomes such as NYHA class. | No - high risk of bias. No ITT done. 7 of 58 enrolled patients did not make it to f/u and though outcomes are briefly and incompletely described for these patients they are not included in analyses. Additionally, only 48 of the 58 pts were included in the hospitalization outcome and the reasons for the discrepant numbers are not explained. | No - high risk of bias. No protocol available. The incomplete reporting of all enrolled patients raises suspicion that not all outcomes were reported. Further, there are signals from within paper that this is so (eg - edema development was a secondary end point but is not reported in results). Other secondary end points are incompletely described (“no significant changes in myocardial events was seen”) | No serious baseline imbalances between groups. | Overall: high risk of bias
Parissis, 2008^18^ | Yes | Unclear | Yes - single blind. Personnel not blinded, but outcome assessors were | Yes | Unclear | No serious baseline imbalances between groups. It is unclear if there is any overlap between patients in this study and Parissis 2009 – if so, then possible multiple publication bias | Overall: low risk of bias
Parissis, 2009^16^ | Yes | Unclear | Yes - single blind. Personnel not blinded but outcome assessors were | Yes | Unclear | No serious baseline imbalances between groups. It is unclear if there is any overlap between patients in this study and Parissis 2008 - if so, then possible multiple publication bias | Overall: low risk of bias
Pfeffer, 2009^14^ | Yes | Unclear | Yes | Yes - 13% attrition, but equally balanced between two groups | Unclear | No serious baseline imbalances between groups | Overall: low risk of bias
Ponikowski, 2007^23^ | Yes | Yes | Yes | Yes | Unclear | No serious baseline imbalances between groups Some evidence of spin: QOL assessed by three measures and improvement seen only in one measure, not the other two, yet conclusions suggest ESA improved health related quality of life | Overall: low risk of bias
Silverberg, 2001^25^ | Unclear | No “Randomization… not done in a blinded fashion” | No | Unclear - Nowhere in the results is the denominator actually reported so it is unclear what the final n was used to calculate results. | Unclear | No serious baseline imbalances between groups | Overall: high risk of bias
Van Veldhuisen, 2007^22^ | Yes | Yes | Yes | Yes | Unclear | No serious baseline imbalances between groups | Overall: low risk of bias

Appendix C, Table 2 Assessment of methodologic characteristics and risk of bias in randomized controlled trials of RBC transfusion for anemia in patients with CHF or CHD

Study ID | Was the allocation sequence adequately generated? | Was allocation adequately concealed? | Blinding of participants, personnel and outcome assessors: Was knowledge of the allocated intervention adequately prevented? | Were incomplete outcome data adequately addressed? | Are reports of the study free of suggestion of selective outcome reporting? | Other sources of bias: Was the study apparently free of other problems that could put it at a high risk of bias? | Summary assessment: risk of bias (Low, Unclear, High)
Bracey, 1999^65^ | Unclear: last digit of HR# determined group assignment | Unclear, concealment method not described | Study not described as blinded. | Yes | Yes | No serious baseline imbalances between groups. | Overall: Unclear risk of bias
Bush, 1997^67^ | Unclear: randomization method not specified | Yes (sealed envelopes) | Study not described as blinded. Surgeons and anesthesiologists were not blinded. | Yes | Yes | No serious baseline imbalances between groups. | Overall: Low risk of bias
Carson, 1998^68^ | Yes: automated telephone-response system at a separate research institute. | Yes: automated telephone-response system at a separate research institute. | Outcome assessors were blinded; blinding was not otherwise specified for patients or care personnel. | Yes | Yes | No serious baseline imbalances between groups. | Overall: Low risk of bias
Carson, 2009^69^ | Unclear: randomization method not described (abstract only) | Not described (abstract only) | Not described (abstract only) | Not described (abstract only) | Yes | No serious baseline imbalances between groups. | Overall: Probably low; study is based on the pilot trial above (Carson 1998)
Cooper, 2011^40^CRIT trial | Unclear: randomization method not specified | Yes (opaque envelopes) | No: “Blinding of treatment assignment was not feasible” | Yes; 6.7% loss to follow-up | Yes | More smokers in conservative group (10% v 33%); more diabetes in liberal group (81% v 54%); P-values not specified. | Overall: Low risk of bias
Hajjar, 2010^66^ | Yes (random numbers table) | Yes (opaque envelopes) | Patient and outcome assessors were blinded to group assignment. Anesthesiologist and ICU health care workers were not blinded. | Yes | Yes | No serious baseline imbalances between groups. | Overall: Low risk of bias
Hebert, 2001^39^TRICC trial | Unclear: randomization method not specified | Unclear, concealment method not described | Outcome assessors were blinded; care personnel were not blinded; patient blinding not specified. | Yes | Yes | No serious baseline imbalances between groups. | Overall: Low risk of bias
Johnson, 1992^64^ | Yes (random numbers table) | Unclear, concealment method not described | Surgeons and anesthesiologists were blinded until patient in ICU. Blinding of outcome assessor and patient not specified. | Yes. No in-hospital deaths occurred. | Yes | No serious baseline imbalances between groups. | Overall: Low risk of bias
Weisel, 1984^63^ | Unclear: randomization method not specified | Unclear, concealment method not described | Use of blinding was not stated. | Yes | Yes | No serious baseline imbalances between groups. | Overall: Low risk of bias

Appendix C, Table 3 Assessment of methodologic characteristics and risk of bias in observational studies of RBC transfusions for anemia in patients with CHD/CHF, stratified by patient population

Author Year | Non-biased selection? | High overall loss to follow-up or differential loss to follow-up? | Outcomes pre-specified and defined? | Ascertainment techniques adequately described? | Non biased and adequate ascertainment methods? | Statistical analysis of potential confounders? | | | | Adequate duration of follow-up?
Author Year | Non-biased selection? | High overall loss to follow-up or differential loss to follow-up? | Outcomes pre-specified and defined? | Ascertainment techniques adequately described? | Non biased and adequate ascertainment methods? | Propensity matching | Account for bleeding | Account for timing of transfusion | Comments | Adequate duration of follow-up?
Percutaneous Coronary Intervention
Chase, 2008^48^ Multicenter Canada | Yes | No | Yes | Yes | Yes | Yes | No | No | Multivariate analysis did not account for some important confounders such as CHF | 30 day and 1 year
Doyle, 2008^47^ Mayo clinic USA | Yes | Not reported | Yes | No. Hospital complication registry but method of follow-up not stated | Not reported | No | No | No | Confounders not reported | Unclear, 30 day mortality reported, but graphs show 5-6 year mortality trends.
Jani, 2007^49^ | Yes | No | Yes | Yes | Yes | Yes | Yes | No | | Yes
Jolicoeur, 2009^50^ | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | | Yes
Kim, 2007^45^ Single center USA | Yes | No | Yes | Yes | Yes | Yes | Yes | No | | 1 year
Kinnaird, 2003^44^ Single center USA | Yes | Probably No. Lost 14%. Difference in loss between groups not reported. | Yes | Yes | Yes | No | Yes | No | | 1 year
Maluenda, 2009^36^ Single Institution USA | Yes | Not reported | Yes | Yes | Probably yes | No | Yes | No | | 30 days and 1 year.
Maluenda, 2009^37^ | Unknown. Abstract only reports # of charts reviewed. Probably yes as is likely same cohort as above. | Not reported | Yes. | No. | Probably yes as likely is same registry as above. But unknown based on this abstract. | Abstract only, may be same population as other Maluenda reference | | | | 1 year
Maluenda, 2009^38^ | Unknown Abstract only reports # of charts reviewed. Probably yes as is likely same cohort as above. | Not reported | Yes | No. | Probably yes as likely is same registry as above. But unknown based on this abstract. | Abstract only, may be same population as other Maluenda reference | | | | 1 year
Nikolsky, 2009^51^ | Yes | No | Yes | Yes | Yes | Yes | Yes | No | | Yes
Yatskar, 2007^46^ Multicenter USA | Yes | No | Yes | Mostly yes. NHLBI registry. Telephone follow-up. But unclear why they looked at “Hematoma Related Transfusion” rather than transfusion. | Probably yes. Again, didn't look at transfusions, only hematoma related transfusions. | No | No – only examined transfusions for hematoma, but not for other causes or for transfusion without bleeding. | No | Confounders not reported and appears a number of important confounders were probably not accounted for | 1 year
Acute Coronary Syndrome/Acute MI
Aggarwal, 2011^60^ | Partly - unclear whether transfusion administration was prospectively collected data for all potentially eligible patients. | No | Yes | No, but primary outcome was in-hospital death. | Yes, probably | No | Yes | No | | Yes
Alexander, 2008^55^ | Yes | No | Yes | Yes | Yes | No | No | No | | Yes
Aronson, 2008^58^ | Yes | Not reported | Yes | Yes | Unclear if investigators doing chart review on repeat admissions were blinded to whether patient had transfusion. | Yes | No | No | | Yes
Rao, 2004^52^ | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | | Yes
Sabatine, 2005^57^ | Yes | No | Yes | Yes | Yes | No | Yes | No | | Yes
Shishehbor, 2009^56^ | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | Also conducted sensitivity analyses to determine impact of “hidden” biases and found there would have to be “enormous” hidden biases to account for results | Yes
Singla, 2007^54^ | Yes | No | Yes | Yes | No, 30 day event rates limited to VA hospitals only. | No | No | No | | Yes
Wu, 2001^59^ | Yes | No, probably - primary outcome 30 D mortality assessed using Medicare Enrollment database, but proportion with complete vital status at 30 D unclear. | Yes | Yes | Yes, probably. | Yes | No | Partly – conducted additional analysis excluding patients who died within two days of admission. | Unclear how well transfusion administration was captured by claims data. | Yes
Yang, 2005^53^ | Yes | Unclear - CRUSADE QI initiative relies on retrospective chart review. | Yes | No | No - in-hospital outcomes only, unclear whether post-discharge deaths were accounted for. | No | No | No | | No
Congestive Heart Failure
Garty, 2009^61^ | Yes | No | Yes | Yes | Yes | Yes | No | No | | Yes
Kao, 2011^62^ | Yes | No | Yes | Yes | Yes | No | No | No | | Yes
Critical Illness
Hebert, 1997^71^ | Unclear - consecutive patients, but 40% were retrospectively identified and patient identification methods not well-described. | Unclear | Yes | No | Unclear | No | No | No | | Yes
Surgery
Bursi, 2009^41^ | Yes | Unclear - number of patients with complete 30 day survival information not reported | Yes | Partly | Partly - 30 day mortality assessed through review of death certificates and phone interviews, but not clear they looked at death registries | Yes | Yes | Yes | | Yes
Carson, 1998^81^ | Yes | No | Yes | Yes | Yes | Yes | Yes | Unclear | | Yes
Glance, 2011^70^ | Yes | No | Yes | Yes | Yes | Yes | No | No | Did not account for post-operative transfusions. | Yes