# INCLUSION/EXCLUSION CRITERIA

1. Is the full text of the article in English?
  Yes............................................................Proceed to #2
  No................................................................ Code X1. STOP
2. Does the study population include adult patients with congestive heart failure or coronary heart disease, and anemia or iron deficiency?
  Yes............................................................Proceed to #3
  No............................................ Code X2. Proceed to #8
3. Is the article an intervention study (or a systematic review/meta-analysis of intervention studies) comparing the effects of ESAs, iron, or red blood cell transfusions with usual care or placebo; or an observational study of the effects of red blood cell transfusions?
  Yes............................................................Proceed to #4
  No.....................................................................Go to #5
4. Does the study report outcomes that include mortality, hospitalization, exercise tolerance, cardiovascular events, quality of life, or adverse effects of treatment?
  Yes.....................................................Code I4. Go to #6
  No ................................................... Code X4. Go to #7
5. Is the article an observational study that reports data on the harms of using ESAs or iron?
  Yes.............................................Code I5. Proceed to #6
  No............................................ Code X5. Proceed to #7
6. Does the article describe or analyze the costs of treatment or implementation?
  Yes..................................................Add Code C. STOP
  No.........................................................................STOP
7. Does the article describe or analyze the costs of treatment or implementation?
  Yes..................................................Add Code C. STOP
  No.............................................................Proceed to #8
8. Is the article potentially useful for background, discussion, or reference-mining?
  Yes..........................................................Code B. STOP
  No.........................................................................STOP