# SEARCH STRATEGY

anemia | anemia anaemia anemia/
congestive heart failure/ coronary heart disease/ ischemic heart disease | cardiac failure chf congestive heart failure coronary heart disease ischemic heart disease heart failure/ coronary disease/ myocardial ischemia/
Erythropoiesis-stimulating agents | anti-anaemi* antianaemi* antianemi* anti-anemi* aranesp darbepoetin darbepoietin darbopoetin epo epoetin epogen epoietin eprex Erythopoiesis-stimulating agents erythropoesis erythropoetin erythropoiesis erythropoietin ESA ESAs hematinics neorecormon nesp procrit recormon rheupo erythropoetin/
Iron - IV or PO | ferric ferrous iron iron/
red blood cell transfusion | red blood cell transfusion Erythrocyte Transfusion/
benefits
harms | safe safety side-effect* undesirable effect* treatment emergent tolerability toxicity adverse adj2 (effect or effects or reaction or reactions or event or events or outcome or outcomes) /adverse effects /poisoning /toxicity /chemically induced /contraindications /complications thromboembolism thromboembolism/
threshold hemoglobin value | threshold hemoglobin value
RCT | 1. randomized controlled trial.pt.; 2. controlled clinical trial.pt.; 3. randomized.ab.; 4. placebo.ab.; 5. drug therapy.fs.; 6. randomly.ab.; 7. trial.ab.; 8. groups.ab; 9. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8; 10. exp animals/ not humans.sh.; 11. 9 not 10; [Cochrane's Highly Sensitive Search Strategy for identifying randomized trials in MEDLINE: sensitivity-maximizing version (2008 revision); Ovid format]
human | not (not human)

Databases: MEDLINE, Cochrane, EMBASE

## ESA Benefits – search strategy

Database(s):Ovid MEDLINE^®^ and Ovid OLDMEDLINE^®^ 1947 to November Week 1 2010, Ovid MEDLINE^®^ In-Process & Other Non-Indexed Citations November 11, 2010

# | Searches | Results
1 | anemia.mp. or exp Anemia/ | 149879
2 | anaemia.mp. | 22339
3 | 1 or 2 | 157901
4 | cardiac failure.mp. or exp Heart Failure/ | 77416
5 | chf.mp. | 8843
6 | congestive heart failure.mp. | 28353
7 | coronary heart disease.mp. or exp Coronary Disease/ | 177123
8 | ischemic heart disease.mp. or exp Myocardial Ischemia/ | 321932
9 | 4 or 5 or 6 or 7 or 8 | 407842
10 | 3 and 9 | 2677
11 | anti-anaemi*.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 33
12 | antianaemi*.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 30
13 | antianemi*.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 174
14 | anti-anemi*.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 94
15 | aranesp.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 83
16 | exp Erythropoietin/ or darbepoetin.mp. | 18912
17 | darbepoietin.mp. | 43
18 | darbopoetin.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 3
19 | epo.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 7585
20 | epoetin.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 2037
21 | epogen.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 61
22 | epoietin.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 51
23 | eprex.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 126
24 | erythropoesis.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 81
25 | erythropoetin.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 164
26 | erythropoiesis.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 15771
27 | erythropoietin.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 23192
28 | ESA.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 1138
29 | ESAs.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 475
30 | hematinics.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 2350
31 | neorecormon.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 31
32 | nesp.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 73
33 | procrit.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 33
34 | recormon.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 30
35 | Erythropoiesis-stimulating agent.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 152
36 | 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 | 37740
37 | randomized controlled trial.pt. | 305853
38 | controlled clinical trial.pt. | 83372
39 | randomized.ab. | 218942
40 | placebo.ab. | 127996
41 | drug therapy.fs. | 1433066
42 | randomly.ab. | 161893
43 | trial.ab. | 227198
44 | groups.ab. | 1067718
45 | 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 | 2717428
46 | exp animals/ not humans.sh. | 3609973
47 | 45 not 46 | 2313774
48 | 10 and 36 and 47 | 225

## ESA Benefits – search strategy, continued

Database(s):EBM Reviews - Cochrane Central Register of Controlled Trials 4th Quarter 2010

Date searched 11/15/10

# | Searches | Results
1 | anemia.mp. or exp Anemia/ | 4561
2 | anaemia.mp. | 985
3 | 1 or 2 | 5004
4 | cardiac failure.mp. or exp Heart Failure/ | 4150
5 | chf.mp. | 1152
6 | congestive heart failure.mp. | 2523
7 | coronary heart disease.mp. or exp Coronary Disease/ | 9300
8 | ischemic heart disease.mp. or exp Myocardial Ischemia/ | 17485
9 | 4 or 5 or 6 or 7 or 8 | 23230
10 | 3 and 9 | 96
11 | anti-anaemi*.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 0
12 | antianaemi*.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 1
13 | antianemi*.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 16
14 | anti-anemi*.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 5
15 | aranesp.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 25
16 | exp Erythropoietin/ or darbepoetin.mp. | 1291
17 | darbepoietin.mp. | 9
18 | darbopoetin.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 9
19 | epo.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 602
20 | epoetin.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 603
21 | epogen.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 2
22 | epoietin.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 18
23 | eprex.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 22
24 | erythropoesis.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 5
25 | erythropoetin.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 32
26 | erythropoiesis.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 449
27 | erythropoietin.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 1903
28 | ESA.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 51
29 | ESAs.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 18
30 | hematinics.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 398
31 | neorecormon.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 19
32 | nesp.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 23
33 | procrit.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 13
34 | recormon.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 7
35 | Erythropoiesis-stimulating agent.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 28
36 | 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 | 2764
37 | randomized controlled trial.pt. | 284694
38 | controlled clinical trial.pt. | 79466
39 | randomized.ab. | 147977
40 | placebo.ab. | 100112
41 | randomly.ab. | 76867
42 | trial.ab. | 102732
43 | groups.ab. | 156434
44 | 37 or 38 or 39 or 40 or 41 or 42 or 43 | 419005
45 | 10 and 36 and 44 | 33

## ESA Benefits – search strategy, continued

Database: EMBASE

Date searched 11/15/10

# | Query | Results
11 | #7 AND #10 | 105
10 | #8 OR #9 | 346115
9 | random$ OR factorial$ OR crossover$ OR cross AND over$ OR ‘cross over$’ OR placebo$ OR doubl$ AND adj AND blind$ OR single$ AND adj AND blind$ OR assign$ OR allocat$ OR volunteer$ AND [embase]/lim | 40406
8 | ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘randomized controlled trial’/exp OR ‘single blind procedure’/exp | 310032
7 | 9 not 10#5 AND #6 | 1015
6 | ‘anti anami$’ OR antianaemi$ OR antianemi$ AND o$r AND ‘anti anemi$’ OR ‘aranesp’/exp OR ‘darbepoetin’/exp OR ‘darbepoietin’/exp OR ‘darbopoetin’/exp OR epo OR ‘epoetin’/exp OR ‘epogen’/exp OR ‘epoietin’/exp OR ‘eprex’/exp OR ‘erythopoiesis stimulating’ AND agents OR erythropoesis OR erythropoetin OR ‘erythropoiesis’/exp OR ‘erythropoietin’/exp OR esa OR esas OR ‘hematinics’/exp OR ‘neorecormon’/exp OR ‘nesp’/exp OR ‘procrit’/exp OR ‘recormon’/exp OR rheupo AND [embase]/lim | 70423
5 | #1 AND #4 | 5587
4 | #2 OR #3 | 376323
3 | ‘heart failure’/exp OR ‘coronary artery disease’/exp | 352502
2 | cardiac AND failure OR chf OR congestive AND ‘heart’/exp AND failure OR coronary AND ‘heart’/exp AND ‘disease’/exp OR ischemic AND ‘heart’/exp AND ‘disease’/exp AND [embase]/lim | 43081
1 | ‘anemia’/exp AND [embase]/lim | 141383

## ESA harms – search strategy

Database(s):Ovid MEDLINE^®^ and Ovid OLDMEDLINE^®^ 1947 to November Week 1 2010, Ovid MEDLINE^®^ In-Process & Other Non-Indexed Citations November 11, 2010

# | Searches | Results
1 | anemia.mp. or exp Anemia/ | 149879
2 | anaemia.mp. | 22339
3 | 1 or 2 | 157901
4 | cardiac failure.mp. or exp Heart Failure/ | 77416
5 | chf.mp. | 8843
6 | congestive heart failure.mp. | 28353
7 | coronary heart disease.mp. or exp Coronary Disease/ | 177123
8 | ischemic heart disease.mp. or exp Myocardial Ischemia/ | 321932
9 | 4 or 5 or 6 or 7 or 8 | 407842
10 | 3 and 9 | 2677
11 | anti-anaemi*.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 33
12 | antianaemi*.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 30
13 | antianemi*.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 174
14 | anti-anemi*.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 94
15 | aranesp.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 83
16 | exp Erythropoietin/ or darbepoetin.mp. | 18912
17 | darbepoietin.mp. | 43
18 | darbopoetin.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 3
19 | epo.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 7585
20 | epoetin.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 2037
21 | epogen.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 61
22 | epoietin.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 51
23 | eprex.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 126
24 | erythropoesis.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 81
25 | erythropoetin.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 164
26 | erythropoiesis.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 15771
27 | erythropoietin.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 23192
28 | ESA.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 1138
29 | ESAs.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 475
30 | hematinics.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 2350
31 | neorecormon.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 31
32 | nesp.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 73
33 | procrit.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 33
34 | recormon.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 30
35 | Erythropoiesis-stimulating agent.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 152
36 | 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 | 37740
37 | exp Thromboembolism/ or thromboembolism.mp. | 47359
38 | (adverse effects or poisoning or toxicity or chemically induced or contraindications or complications).fs. | 2846319
39 | (adverse adj2 (effect or effects or reaction or reactions or event or events or outcomes or outcome)). mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 179933
40 | (safe or safety or side-effect* or undesirable effect* or treatment emergent or tolerability or toxicity). mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 675202
41 | 37 or 38 or 39 or 40 | 3311276
42 | 10 and 36 and 41 | 280

## ESA harms – search strategy, continued

Database(s):EBM Reviews - Cochrane Central Register of Controlled Trials 4th Quarter 2010

Date searched: 11/15/10

# | Searches | Results
1 | anemia.mp. or exp Anemia/c | 4561
2 | anaemia.mp. | 985
3 | 1 or 2 | 5004
4 | cardiac failure.mp. or exp Heart Failure/ | 4150
5 | chf.mp. | 1152
6 | congestive heart failure.mp. | 2523
7 | coronary heart disease.mp. or exp Coronary Disease/ | 9300
8 | ischemic heart disease.mp. or exp Myocardial Ischemia/ | 17485
9 | 4 or 5 or 6 or 7 or 8 | 23230
10 | 3 and 9 | 96
11 | anti-anaemi*.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 0
12 | antianaemi*.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 1
13 | antianemi*.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 16
14 | anti-anemi*.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 5
15 | aranesp.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 25
16 | exp Erythropoietin/ or darbepoetin.mp. | 1291
17 | darbepoietin.mp. | 9
18 | darbopoetin.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 9
19 | epo.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 602
20 | epoetin.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 603
21 | epogen.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 2
22 | epoietin.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 18
23 | eprex.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 22
24 | erythropoesis.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 5
25 | erythropoetin.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 32
26 | erythropoiesis.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 449
27 | erythropoietin.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 1903
28 | ESA.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 51
29 | ESAs.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 18
30 | hematinics.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 398
31 | neorecormon.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 19
32 | nesp.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 23
33 | procrit.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 13
34 | recormon.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 7
35 | Erythropoiesis-stimulating agent.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 28
36 | 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 | 2764
37 | exp Thromboembolism/ or thromboembolism.mp. | 2067
38 | (adverse adj2 (effect or effects or reaction or reactions or event or events or outcomes or outcome)). mp. | 48156
39 | (safe or safety or side-effect* or undesirable effect* or treatment emergent or tolerability or toxicity). mp. | 95206
40 | 37 or 38 or 39 | 114226
41 | 10 and 36 and 40 | 10

## ESA harms – search strategy, continued

Database: EMBASE

Date searched: 11/15/10

# | Query | Results
11 | #7 AND #10 | 412
10 | #8 OR #9 | 1154469
9 | safe OR ‘safety’/exp OR ‘side effect$’ OR undesirable AND effect$ OR treatment AND emergent OR tolerability OR ‘toxicity’/exp OR (adverse AND adj2 AND (effect OR effects OR reaction OR reactions OR event OR events OR outcome OR outcomes)) AND [embase]/lim | 432305
8 | ‘complication’/exp OR ‘side effect’/exp OR ‘adverse drug reaction’/exp OR ‘drug toxicity’/exp | 899447
7 | #5 AND #6 | 1015
6 | ‘anti anami$’ OR antianaemi$ OR antianemi$ AND o$r AND ‘anti anemi$’ OR ‘aranesp’/exp OR ‘darbepoetin’/exp OR ‘darbepoietin’/exp OR ‘darbopoetin’/exp OR epo OR ‘epoetin’/exp OR ‘epogen’/exp OR ‘epoietin’/exp OR ‘eprex’/exp OR ‘erythopoiesis stimulating’ AND agents OR erythropoesis OR erythropoetin OR ‘erythropoiesis’/exp OR ‘erythropoietin’/exp OR esa OR esas OR ‘hematinics’/exp OR ‘neorecormon’/exp OR ‘nesp’/exp OR ‘procrit’/exp OR ‘recormon’/exp OR rheupo AND [embase]/lim | 70423
5 | #1 AND #4 | 5587
4 | #2 OR #3 | 376323
3 | ‘heart failure’/exp OR ‘coronary artery disease’/exp | 352502
2 | cardiac AND failure OR chf OR congestive AND ‘heart’/exp AND failure OR coronary AND ‘heart’/exp AND ‘disease’/exp OR ischemic AND ‘heart’/exp AND ‘disease’/exp AND [embase]/lim | 43081
1 | ‘anemia’/exp AND [embase]/lim | 141383

## Iron benefits and harms

Database(s):Ovid MEDLINE^®^ and Ovid OLDMEDLINE^®^ 1947 to November Week 1 2010, Ovid MEDLINE^®^ In-Process & Other Non-Indexed Citations November 11, 2010

# | Searches | Results
1 | anemia.mp. or exp Anemia/ | 149879
2 | anaemia.mp. | 22339
3 | 1 or 2 | 157901
4 | cardiac failure.mp. or exp Heart Failure/ | 77416
5 | chf.mp. | 8843
6 | congestive heart failure.mp. | 28353
7 | coronary heart disease.mp. or exp Coronary Disease/ | 177123
8 | ischemic heart disease.mp. or exp Myocardial Ischemia/ | 321932
9 | 4 or 5 or 6 or 7 or 8 | 407842
10 | 3 and 9 | 2677
11 | exp Iron/ or iron.mp. | 133944
12 | ferric.mp. | 18656
13 | ferrous.mp. | 12391
14 | 11 or 12 or 13 | 145012
15 | 10 and 14 | 400

## Iron benefits and harms – search strategy, continued

Database(s):EBM Reviews - Cochrane Central Register of Controlled Trials 4th Quarter 2010

Date searched: 11/15/10

# | Searches | Results
1 | anemia.mp. or exp Anemia/ | 4561
2 | anaemia.mp. | 985
3 | 1 or 2 | 5004
4 | cardiac failure.mp. or exp Heart Failure/ | 4150
5 | chf.mp. | 1152
6 | congestive heart failure.mp. | 2523
7 | coronary heart disease.mp. or exp Coronary Disease/ | 9300
8 | ischemic heart disease.mp. or exp Myocardial Ischemia/ | 17485
9 | 4 or 5 or 6 or 7 or 8 | 23230
10 | 3 and 9 | 96
11 | exp Iron/ or iron.mp. | 3384
12 | ferric.mp. | 365
13 | ferrous.mp. | 604
14 | 11 or 12 or 13 | 3566
15 | 10 and 14 | 24

## Iron benefits and harms – search strategy, continued

Database: EMBASE

Date searched: 11/15/10

# | Query | Results
11 | #5 AND #10 | 593
10 | #8 OR #9 | 112969
9 | ferric OR ferrous OR ‘iron’/exp AND [embase]/lim | 85359
8 | ‘iron’/exp | 88060
5 | #1 AND #4 | 5587
4 | #2 OR #3 | 376323
3 | ‘heart failure’/exp OR ‘coronary artery disease’/exp | 352502
2 | cardiac AND failure OR chf OR congestive AND ‘heart’/exp AND failure OR coronary AND ‘heart’/exp AND ‘disease’/exp OR ischemic AND ‘heart’/exp AND ‘disease’/exp AND [embase]/lim | 43081
1 | ‘anemia’/exp AND [embase]/lim | 141383

## RBC transfusion benefits and harms – search strategy

Database(s):Ovid MEDLINE^®^ and Ovid OLDMEDLINE^®^ 1947 to November Week 1 2010, Ovid MEDLINE^®^ In-Process & Other Non-Indexed Citations November 11, 2010

Date searched: 11/12/10

# | Searches | Results
1 | anemia.mp. or exp Anemia/ | 149879
2 | anaemia.mp. | 22339
3 | 1 or 2 | 157901
4 | cardiac failure.mp. or exp Heart Failure/ | 77416
5 | chf.mp. | 8843
6 | congestive heart failure.mp. | 28353
7 | coronary heart disease.mp. or exp Coronary Disease/ | 177123
8 | ischemic heart disease.mp. or exp Myocardial Ischemia/ | 321932
9 | 4 or 5 or 6 or 7 or 8 | 407842
10 | 3 and 9 | 2677
11 | red blood cell transfusion.mp. or exp Erythrocyte Transfusion/ | 5368
12 | 10 and 11 | 46

## RBC transfusion benefits and harms – search strategy continued

Database(s):EBM Reviews - Cochrane Central Register of Controlled Trials 4th Quarter 2010

Date searched: 11/12/10

# | Searches | Results
1 | anemia.mp. or exp Anemia/ | 4561
2 | anaemia.mp. | 985
3 | 1 or 2 | 5004
4 | cardiac failure.mp. or exp Heart Failure/ | 4150
5 | chf.mp. | 1152
6 | congestive heart failure.mp. | 2523
7 | coronary heart disease.mp. or exp Coronary Disease/ | 9300
8 | ischemic heart disease.mp. or exp Myocardial Ischemia/ | 17485
9 | 4 or 5 or 6 or 7 or 8 | 23230
10 | 3 and 9 | 96
11 | red blood cell transfusion.mp. or exp Erythrocyte Transfusion/ | 360
12 | 10 and 11 | 6

## RBC transfusion benefits and harms – search strategy continued

Database(s):EMBASE

Date searched: 11/12/10

# | Query | Results
7 | #5 AND #6 | 205
6 | ‘erythrocyte transfusion’/exp | 8844
5 | #1 AND #4 | 5587
4 | #2 OR #3 | 376323
3 | ‘heart failure’/exp OR ‘coronary artery disease’/exp | 352502
2 | cardiac AND failure OR chf OR congestive AND ‘heart’/exp AND failure OR coronary AND ‘heart’/exp AND ‘disease’/exp OR ischemic AND ‘heart’/exp AND ‘disease’/exp AND [embase]/lim | 43081
1 | ‘anemia’/exp AND [embase]/lim | 141383

## Hemoglobin threshold – search strategy

Database(s):Ovid MEDLINE^®^ and Ovid OLDMEDLINE^®^ 1947 to November Week 1 2010, Ovid MEDLINE^®^ In-Process & Other Non-Indexed Citations November 11, 2010

# | Searches | Results
1 | (hemoglobin adj3 threshold*).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 75

## Hemoglobin threshold – search strategy continued

Database: EMBASE

Date searched: 11/12/10

# | Query | Results
7 | #5 AND #6 | 16
6 | threshold AND ‘hemoglobin’/exp AND [embase]/lim | 972
5 | #1 AND #4 | 5587
4 | #2 OR #3 | 376323
3 | ‘heart failure’/exp OR ‘coronary artery disease’/exp | 352502
2 | cardiac AND failure OR chf OR congestive AND ‘heart’/exp AND failure OR coronary AND ‘heart’/exp AND ‘disease’/exp OR ischemic AND ‘heart’/exp AND ‘disease’/exp AND [embase]/lim | 43081
1 | ‘anemia’/exp AND [embase]/lim | 141383

## Hemoglobin threshold – search strategy continued

Database(s):EBM Reviews - Cochrane Central Register of Controlled Trials 4th Quarter 2010

Date searched: 11/12/10

# | Searches | Results
1 | (hemoglobin adj3 threshold*).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 14