# SUMMARY AND DISCUSSION

## CONCLUSIONS AND RECOMMENDATIONS

In this section, we will summarize the results as they relate to the key questions and provide a series of recommendations for future research on rural health issues.

As evidenced by our review, there were several conditions for which there was a paucity of evidence regarding their prevention, diagnosis or treatment in rural health care settings (e.g., sexually transmitted diseases, rheumatoid arthritis, COPD, chronic pain, hepatitis C, anxiety disorders, substance use disorders, post-treatment cancer surveillance, traumatic brain injury). Studies tended to be conducted in areas in which either the information was readily available in a national database, a performance measure or guideline existed for which there was evidence and which served to operationalize quality care (e.g., via claims data), or a local health care problem existed that the authors were seeking to quantify. Given the data sources, study designs were predominantly cross-sectional or retrospective cohort designs, and only one of the studies we reviewed used a prospective design. Few studies associated health care differences with health outcomes. Given these limitations, the strength of the evidence was at best weak to moderate for most areas even when a significant finding was consistently present. This complicated interpretability. Most of our conclusions, therefore, are at best suggestive.

Another significant conceptual problem with the use of extant data sources and the cross-sectional study designs used was that potential reasons for rural-urban differences were often treated as confounders and adjusted for in statistical models. There are many correlates of rural residency that may affect health care utilization or access (e.g., lower rates of college graduates, types of health insurance, higher rates of poverty in highly rural areas, etc.).119 Statistically adjusting for these contextual characteristics only to then find no difference between rural and urban residents in health outcomes does not mean that rural residents or, in some cases, urban residents are not disadvantaged.120 Similar points have been made in discussions of race disparities,121 with recommendations made to “unpack” the factors underlying the differences, which we feel are also applicable in this area.

Because our evidence base relied on peer reviewed articles, we did not include national reports examining potential differences in rural vs. urban health care. However, because these reports serve to inform policy makers, at the end of this section we compare findings from the 2010 National Healthcare Disparities Report122 and the 2010 VHA Facility Quality and Safety Report123 with the results of this systematic review.

## SUMMARY OF EVIDENCE BY KEY QUESTION

### Key Question #1 Do adults with health care needs who live in rural areas have different intermediate (e.g., HbA1c, Blood pressure, etc.) or final health care outcomes (i.e., mortality, morbidity, QOL) than those living in urban areas?

Most of the evidence regarding potential differences in health care outcomes between rural and urban patients is weak either by the quality of the study designs and/or the paucity of studies evaluating whether any differences exist. Below we list the findings for which there is some evidence of a health care disparity.

- There is some weak evidence that increasing rurality is associated with a greater frequency of hospitalization for ACSC's.
- No evidence for differences in cancer mortality.
- There is some evidence of greater rates of DCIS and lower rates of invasive cervical cancer in urban areas where screening rates are higher.
- There was no evidence for a disparity between rural and urban patients with diabetes in terms of diabetes complications or the prevalence of ESRD. However, there was some evidence that race by rurality interactions may exist in diabetes care and in the treatment of ESRD.
- Although very limited, the available information suggests that outpatient control of hypertension, at least among veterans, does not differ between those residing in rural vs. urban areas.

There was weak evidence for higher hospitalization rates for rural residents treated for depression in Arkansas.

### Key Question #2 Is the structure (e.g., types of available providers) or the process (e.g., likelihood of referral) of health care different for adults with health care needs who live in urban vs. rural environments?

#### Use of Medication

No consistent differences were found in receipt of or adherence to medication. To the extent that a few studies reported any differences, urban residents tended to receive more medications.

#### Medical Procedures and Diagnostic Tests

The use of most services, including office visits and consultations, imaging services, and diagnostic testing, were found to be lower in rural areas compared to urban areas. More consistent evidence was found specifically for lower screening rates for breast and cervical cancer in many rural areas. Differences in screening rates for colorectal cancer are not consistently found. However, all but one study found a greater frequency of unstaged cancer at the time of diagnosis in rural areas compared to urban areas.

#### Medical Appointments with Providers

Rural residents were less likely to see a medical provider than urban residents. Specifically, rural residents were less likely to see specialists, and low availability of specialists had deleterious impact on some health outcomes (e.g., cancer mortality). However, studies did not generally account for the fact that rural residents often receive specialty health care in urban clinics and how this might affect health outcomes. More consistent was the lower rate of mental health care service receipt among residents in rural areas.

#### Usual Source of Care

There was no consistent evidence that rural residents were less likely to have a usual source of care. In fact, there was more consistent evidence that rural residents had better continuity of care. Having fewer health care choices seems to increase the odds of remaining with the same provider over time.

#### Provider Availability and Expertise

There was consistent evidence that highly rural areas had a paucity of health care providers. There was some evidence that providers in some highly rural areas were more likely to be physician extenders (e.g., physician assistants, nurse practitioners). There was some weak evidence that physician extenders in some rural areas may not have comparable credentials to their urban counterparts. More consistent evidence was found indicating that rural residents were more likely to have primary care providers whose training was in family medicine rather than general internal medicine or OB/GYN. There was also consistent evidence that rural residents had less access to specialty medical services unless they traveled to urban health care centers. Fewer non-physician rehabilitation specialists are available in rural areas.

There was weak evidence provided by one study that suggested that limitations in provider knowledge might impact clinical practice viz. colorectal cancer screening.

The two studies examining the availability of rehabilitation specialists both found a paucity of such providers in many rural areas relative to urban areas. One of the studies compared availability over several years, increasing confidence in this finding. Similarly, there is a fairly consistent finding of fewer mental health specialists in rural areas.

#### Quality of Care

There were also no consistent differences between rural and urban areas in treatment quality measures for diabetes, although one study found evidence for regional variation in rural disparities. This was not assessed in other studies. Similarly, the two larger studies of treatment of hypertension did not find any quality differences between rural and urban settings.

Although the studies are few, there is some evidence suggesting that care for some conditions (e.g., HIV/AIDS) may be lower in rural areas. Two of three studies examining quality of cancer treatment indicated lower quality of care in rural areas. The third, however, found that rurality was less of a contributor to quality care differences than was provider characteristics.

### Key Question #3 If there are differences in the structure or the process of health care in rural vs. urban environments, do those differences contribute to variation in overall or intermediate health outcomes for adults with health care needs?

Although there were many studies that documented differences in health care structure or process between urban and rural health care settings, as we noted above few associated those differences with variation in health outcomes. The list of findings below is generally based on single studies of variable quality. Results can only be considered suggestive.

- Lower rates of mammography and cervical cancer screening in rural areas was associated with lower rates of ductal carcinoma in situ (vs. more invasive breast cancer) and higher rates of invasive cervical cancer in rural areas.
- Improving access by the creation of Rural Health Clinics in underserved areas was associated with improved adherence to treatment guidelines for diabetes.52
- Limited numbers of providers in rural areas may foster better continuity of care.
- Limitations in provider availability may be associated with increased odds of hospitalization among older rural residents for ACSCs.

Two studies that were published after our sampling frame demonstrate comparable rates of pharmacotherapy for rural and urban residents with depression and rural vs. urban veterans with depression or anxiety disorders.124,125 Both studies found that the odds of having psychotherapy appointments, however, were lower among those who lived in rural settings, and that this difference was mediated by provider availability.

### Key Question #4 If there are differences in intermediate or final health outcomes for adult patients with health care needs, what systems factors other than those due to differences in health care structure or process moderate those differences (e.g., travel distance)?

#### Insurance

- Lack of insurance was associated with increased odds of ACSC associated admissions, but this was not limited to rural residents; however, within rural areas those who had supplemental HMO plans had fewer admissions compared to older residence with a fee-for-service insurance plan. Of note, one study found that Medicare HMO enrollees had to travel further for acute care services than Medicare fee-for-service patients, and were less likely to receive services within their county.126

#### Travel Distance

- There was limited evidence that having a greater distance to treatment decreased odds of receipt of radiotherapy for older women with breast cancer, aftercare for veterans treated in inpatient alcohol treatment programs, and frequency of mental health appointments.
- The presence of Rural Health Clinics in underserved areas improved treatment access and adherence to treatment guidelines for patients with diabetes.

#### Patient Attitude

- There is some weak evidence that urban residents may have a lower threshold for seeking mental health care than do rural residents, and that this may be related to differential use of mental health services.

#### Race Disparities

- For many conditions covered in this review, race disparities were greater in urban than in rural areas. This was observed in admissions for ACSC-related conditions, stage at presentation for colorectal and prostate cancers, detection of diabetes, secondary prevention for diabetes-related conditions, post-hospitalization continuity of care for mental illness, and, among Native Americans, the odds of receiving a kidney transplant.
- Race disparities were greater in rural areas for mortality rates among Hispanics for ESRD and for rates of organ transplants for blacks.

The 2010 National Healthcare Disparities Report (NHDR) compared health outcomes between noncore areas (defined as rural counties without metropolitan or micropolitan areas) with large fringe metropolitan areas (defined as suburban counties of metropolitan areas with one million or more residents).122 Most of their findings relating to adult ambulatory healthcare, found results comparable to this review. Specifically, the NHDR also found evidence for increased hospitalizations for ACSC's, elevated suicide rates, reduced rates of CRC screens and lower insurance rates among rural residents. Differences in the NHDR and this review were only noted for lung and CRC related mortality rates and the odds of flu vaccination (they found disparities, we found the evidence to be inconsistent for cancer care). Importantly, it must be noted that the studies covered by this review most often compared rural areas with urban areas, not suburban areas. Given that we found urban disparities in some healthcare areas (notably cancer care), this might account for the differential findings. Finally, the NHDR reported differences in a few areas for which no articles were included in this review -- advice for exercise among obese patients and the five year odds of cholesterol screening -- both of which demonstrated a rural disadvantage.

The 2010 VHA Facility Quality and Safety Report compared US census defined urban areas with non-urban areas (called rural, but which would include suburban counties).123 Only bivariate findings are included in the report. Comparable to this evidence synthesis, no differences were noted for guideline concordant follow-up care for patients with diabetes, control of hypertension, or immunization rates for influenza. Also assessed in that report, but not covered by this evidence synthesis, were patient satisfaction, counseling for tobacco cessation and mental health screens, none of which demonstrated consistent differences between rural and urban areas nationally. Despite the similarities, it is difficult to conclude that no differences between highly rural and urban (or suburban) areas exist because of the way VA categorizes urban vs. rural.

## RESEARCH IMPLICATIONS AND RECOMMENDATIONS

As has been shown by others, the definition of rural that is used in a study has a significant impact on the findings and, consequently, the policy implications.11,12,14 Yet, there is little consistency across studies either in terms of what convention is used to define rural or how a chosen convention is actually employed in the study. Consequently, we make the following recommendations for researchers regarding definitions of “rural” and other methodologic issues based on our observations and the work of others.11,12,14

1. Specify the convention that was used to define “rural” in the study and how it was specifically operationalized. Many studies use rural–urban commuting area codes (RUCA) as their starting point, but then combine the categories in unique ways. The convention used by VA may minimize rural-urban disparities for some healthcare services. A more graded convention (e.g., RUCA, RUCC or UIC) would allow for better identification of areas in need of intervention.
2. Provide a rationale for why the convention used in the study was chosen and the potential impact of that choice on the research question (e.g., Is a monotonic relationship between levels of population density and the outcome variable expected?).
  a. Consider using a statistical method for deciding between conventions if more than one option is available.12
3. If the study questions do not call for a clear choice in the convention to be used, consider using more than one convention and reporting the results for both definitions.
4. Provide a rationale for the unit of analysis viz. the research question. For example, does the unit of analysis reflect the functioning of local health care systems or markets (e.g., county vs. zip code as unit of analysis) or is the focus individual health outcomes?
  a. Associations between health care parameters and specific health outcomes found when using aggregate units (e.g., counties or zip codes) may not hold at the individual level (i.e., a modifiable areal unit problem). This limitation was generally not acknowledged.

As noted by Rost et al.,127 many of the important questions concerning rural-urban disparities in health care cannot be answered by simply demonstrating differences in health care systems. A more useful set of questions focus on clarifying what health outcomes, if any, show a disparity, for whom does the disparity exist, and why is there a disparity. Accordingly, we make the following recommendations.

1. Because many factors are correlated with rurality, adjusting for all available covariates may lead to false conclusions regarding the association of rurality and study outcomes, and provide insufficient information for the development of healthcare policy. For most research questions, a more contextual analytic approach should be used.
  a. For example, first reporting bivariate associations (missing from many papers) and then examining which, if any, of the available covariates significant in multivariable models contributed to the observed differences in the bivariate analyses. Alternatively, other statistical models, such as multilevel models, might be useful.
  b. These associations must also be considered when selecting instrumental variables or developing propensity models for risk adjustment.
2. Most rural residents receive their primary health care locally. However, a significant proportion of rural residents will travel to more urban areas for medical conditions that require specialist treatment or for which they have less confidence in the expertise of their usual provider111 Few studies acknowledged this trend, and those that did generally omitted data from those individuals who received their care in urban settings. Studies should address this selection bias and seek to understand its implications for their study findings and for the health care systems involved.
3. In several studies, interactions were found between race (and/or income) and residential population density. Such interactions may have significant implications for interventions designed to address a rural health disparity, and should be tested in the research model if appropriate. Interactions between race and rurality should be further explored as they could reflect any of the following (see Stern, 2010^12^ for a discussion):
  a. Living in a rural or urban area affects health care (or access to health care) for a minority group differently than it does for whites.
  b. The association is due to the distribution of minority members of the patient group in question.
  c. A third factor is associated with both race and rurality (e.g., poverty)
  d. There is an association between race and some aspect of the healthcare system (e.g., proportion of providers who are minorities).
4. Studies that describe differences in healthcare systems but do not associate such differences with health outcomes are of limited value. Areas with limited healthcare resources may engage in successful service substitution and areas with an abundance of health care resources may engage in overutilization.
5. Only one of the studies we reviewed that compared rural with urban health care used a prospective design. This limits the confidence with which factors associated with a rural disparity can be considered as potentially causal.
6. Studies focused on providing descriptions of barriers to care are only helpful insofar as the barriers are associated with actual limitations in the use of needed healthcare services. All consumers have barriers to care, but not all barriers limit health care seeking.
7. Large national databases often involve statistical corrections to adjust for any potential sampling bias. Using such databases improves a study's external validity; however, the findings from such secondary analyses are often limited by what measures are available in the database.
8. Studies that relied on self-report measures rarely assessed or corrected for sampling bias, and many did not include sampling bias as a possible study limitation. Similarly, studies sampling from multiple sites often did not address potential clustering effects in their analyses.
9. Studies that sample nationally should consider examining whether there is regional variation in observed rural-urban disparities. Regional variation in rural-urban disparities has been demonstrated in studies involving veterans4 and non-veterans.31,51 Pooling across regions may attenuate disparities. Moreover, health care systems operate locally and identifying areas where problems are greatest would help policy makers target areas that have the most need.

There are large gaps in the evidence base across clinical conditions, and minimal empirical work conducted on several areas of particular interest to the VA (e.g., TBI, PTSD, Hepatitis C). Filling in the evidence base will allow VA policy planners to make informed decisions about resource allocation.