# RESULTS

## LITERATURE FLOW

The literature flow is presented in Figure 2. The combined search library contained 1,381 citations, of which we reviewed 333 articles at the full-text level. We excluded 165 of the 333 articles and added 24 references through hand-searching reference lists of relevant articles and The Journal of Rural Health. Of 192 possible studies, we excluded 93 because they were not related to ambulatory care, described an intervention, or provided background information. Three studies were added based on comments received during peer-review resulting in 102 articles reporting data pertaining to one of the key questions. The included articles were categorized under the following ambulatory care services: preventive care/ambulatory care sensitive conditions, cancer care, diabetes/end stage renal disease, cardiovascular disease, HIV/AIDS, neurologic conditions, and mental health. We also identified and included articles focused on use of medication, medical procedures and tests, and provider and service utilization more generally.

Figure 2 Flow Diagram of Included Studies

## PREVENTIVE CARE/AMBULATORY CARE SENSITIVE CONDITIONS

(Table 3 and Appendix C, Tables 1 and 2)

Table 3 Confidence Scores for Preventive Care/Ambulatory Care Sensitive Condition Studies

Study | Casey 2001^18^ | Zhang 2000^19^ | Kinney 2006^24^ | Epstein 2009^27^ | Laditka 2009^28^ | Schreiber 1997^30^ | Saag 1998^29^ 18 | Coughlin 2002^21^ | Coughlin 2004^22^ | Coughlin 2008^23^ | Stearns 2000^26^ | Brown 2009^20^ | Schootman 1999^25^
Internal Validity | G | G | G | F | G | F | F | G | G | G | G | G | G
Sampling Method/Bias | G | G | G | F | G | G | F | G | G | G | G | G | G
Predictors/Confounders | G | G | G | G | G | F | G | G | G | G | G | G | G
Outcomes | G | G | G | F/P | G | G | F | G | G | G | G | G | G
Statistical Methods | G | G | G | G | G | F | G | G | G | G | G | G | G
External Validity | G | F | G | F | F | F | F | G | G | G | F | F | F
Use of proxy variables or aggregate measures | G | G | G | G | F | F | F | G | G | G | G | G | F
Sample Representativeness (size, composition) | G | F | G | F | G | G | G | G | G | G | F | G | G
Design appropriate for the research question | G | G | F | G | G | F | G | G | G | G | G | F | F
Overall Confidence Score | H | M | M | M/L | M | L | L | H | H | H | M | M | M

There were two studies looking at immunization rates,18,19 nine looking at cancer screening rates,18-26 one examining prenatal care,27 and three examining hospital rates for ambulatory care sensitive conditions.28-30

Immunization rates were examined in only two studies, both using data more than 10 years old. Among respondents to the 1994 US National Health Interview Survey, the rate of flu shot receipt among 4,051 people over 65 yr was examined.19 No differences were observed between older rural and urban residents in the receipt of flu vaccine in adjusted analyses. Similarly, national data of 130,452 respondents from the 1997 Behavioral Risk Factor Surveillance System (BRFSS) and the 1999 Area Resource File found no rural-urban differences in the rates of either flu or pneumonia vaccines among women age 65 years and older.18

Only one study examined prenatal care.27 This study used the 2003 Oregon Pregnancy Risk Assessment Monitoring System to examine the odds of receiving prenatal care after the first trimester in RUCA defined urban, large rural and small rural areas among 1,508 women. Women were surveyed post childbirth about when during their pregnancy they initiated prenatal care (if at all). No differences were found between residence categories in the odds of late initiation (after first trimester) of prenatal care. However, given methodologic problems with the study, our confidence in this finding is moderately low.

Ambulatory care sensitive conditions (ACSC) are those conditions in which inadequate outpatient treatment leads to increases in hospitalization.30 Conditions that are considered to be ambulatory care sensitive include congestive heart failure (CHF), hypertension, angina, chronic obstructive pulmonary disease, as well as other conditions in which hospitalization can usually be avoided, such as bacterial pneumonia, cellulitis, diabetes, gastroenteritis, asthma, and urinary tract infections. A study of the prevalence of ACSC hospital admissions in New York State from 1991-1993 found that the rates increased as population density decreased within each of the demographic groupings (New York City area, upstate urban-suburban areas, more remote rural). They did not compare across areas. Of note, the percentage of blacks was positively associated with the rate of ACSC admissions in the two more populous groupings.30 In a much better designed study, Laditka (2009) examined ACSC admissions in 8 states during 2002.^28^ They reported a step-wise increase in the rate ratios of admissions for patients 18-64 years across levels of rurality adjusted for demographics and availability of health care services. Although further adjustment for death rates from chronic diseases (e.g., heart disease) did not change the association appreciably, adjustment for percentage of population that was uninsured reduced the association across all levels of population density, suggesting that insurance-related access contributed to the variation across the spectrum of population density. However, since rates in the most rural areas remain elevated relative to urban rates even after adjusting for insurance (RR=1.28, 95%CI=1.12-1.47) the contribution of insurance possession to the population density effect is only partial. For patients 65 years or older, the step-wise increase in ACSC admissions was retained when all adjustments were made except for those related to death rates and physician supply (which was not significantly associated with ACSC admissions) (RR=1.46, 95%CI=1.39-1.52 most rural:urban).

A study of secondary and tertiary prevention among 787 older adults with ACSCs (specifically, arthritis, hypertension, coronary heart disease, diabetes mellitus, peptic ulcer disease, and chronic obstructive pulmonary disease [COPD]), was conducted in Iowa in 1995.^29^ No differences were found between rural and urban residents in condition-specific prevention scores, but methodologic limitations of this study resulted in a low Confidence Score, suggesting that these results are likely to change with new information. Although rural residents with these chronic conditions saw fewer specialists than urban residents (7% vs. 12%, p<0.05), and were somewhat less likely to report a need for medical advice in the previous year (50% vs. 58%, p<0.05), they also had better continuity of care than urban residents (100% vs. 83% of time seeing physician they saw most, p<0.001).

The rate of colorectal cancer (CRC) screening was assessed in two national studies, and one regional study. All three studies found a rural disadvantage in screening rates. National data of 130,452 respondents from the 1997 Behavioral Risk Factor Surveillance System (BRFSS) and the 1999 Area Resource File examined CRC screens (fecal occult blood test or proctosigmoidoscopy). Residents from rural areas adjacent or non-adjacent to urban areas were less likely to get CRC screening (ORs=0.83 and 0.82, respectively).18 Similar results were reported using the 1998-1999 datasets of the BRFSS of 23,565 men and 37,847 women over age 50 years.22 In rural areas, 16.2% of residents had a fecal occult blood test vs. 22% in large urban areas. Examining sigmoidoscopy/ colonoscopy rates yielded a similar finding, with 28.2% of rural residents receiving these screens vs. 35.2% of those who live in large urban areas. Although attenuated, these differences remained after adjustments. A case-control study of CRC screening in North Carolina using a nurse led patient interview found fewer rural residents reported CRC screening in the previous 5 years.24 When differences in screening rates were held constant, a rural disparity in the incidence of CRC was eliminated, suggesting a difference in health care access.

There were five studies examining breast and cervical cancer screening rates in national samples. The 1994 US National Health Interview Survey was used to assess, cervical and breast cancer screening (i.e., mammography) among 8,970 age 18 years and older, and among 2,729 women age 50 years and older respectively.19 No differences were observed between rural and urban women in the receipt of cervical cancer screens. Differences were found between urban and rural women in mammography (68% of urban vs. 61 percent of rural; p =0.01). These differences were no longer apparent after adjustment for education, household income and health insurance status. Among the 12,637 patients 65 yr and older and/or disabled who participated in the 1993 Medicare Current Beneficiary Survey, screening rates were lower among women from smaller non-urban counties relative to large urban counties for breast (28.6% vs. 34.4%) and cervical (28.4% vs. 23.1%) cancers in bivariate analyses.26 As with the 1994 National Health Interview study, these differences disappeared after adjusting for income, Medicaid status, physician availability, age, race, education and functional status.

All three studies using the BRFSS datasets found rural-urban differences in breast and/or cervical screening rates. In a study using the 1997 BRFSS database,18 women from rural areas were significantly less likely to get cervical cancer screening (ORs=0.86 and 0.88), while only those from rural areas adjacent to metropolitan areas were less likely to get mammograms (OR=0.82). Factors found to be predictive of screenings included insurance status, availability of primary care providers, and income. A study using the 1998-1999 BRFSS database examined mammography and clinical breast exams among 108,326 women over 40 years old, and cervical cancer screens among 131,813 women over the age of 18 years.21 Among rural women over 40 years old, 66.7% had mammograms and 73% had clinical breast exams. The rates among urban women were 75.4% for mammography and 78.2% for clinical breast exams. Similar differences for cervical cancer screening rates were found, with 81.3% of rural women and 84.5% of the most urban women getting screens. These differences were attenuated with adjustment, but remained significant. Of note, rural-urban differences were greater among black and Hispanic women. Finally, a study examining cervical screening rates using 2002 BRFSS, found that the odds of receiving a Pap test among 91,492 rural women depended on the number of available primary care providers.23 Urban women who lived in counties with fewer providers (i.e., fewer than 300 primary providers per 100,000 women) were more likely to get a Pap test than rural or suburban women from counties with similar provider availability (OR=1.13, 95%CI=1-1.28). In counties in which there were moderate numbers of providers (i.e., 300-500 per 100,000 women), only those in suburban counties were disadvantaged (OR=0.72, 95%CI=0.55-0.94). The odds of mammogram receipt were greater for urban (OR=1.21, 95%CI=1.11-1.32) and suburban (OR=1.28, 95%CI=1.17-1.4) women than rural women independent of provider availability.

In both regional studies in which breast and cervical cancer screening rates were assessed there was a rural disadvantage, though significance remained after adjustment in only one of the studies. Using state BRFSS data from 1996-1997, non-disabled rural women in Iowa were found to have had lower rates of screening for breast (X^2^=5.73, p<0.0001) and cervical (X^2^=6.0, p<0.0001) cancer than their urban counterparts.25 For example, of those from the most rural regions (population density of fewer than 20 people per square mile), only 37.3% received a mammogram and only 61.3% were screened for cervical cancer. In contrast, in the most densely populated areas (100 or more per square mile), 56.4% and 73.7% received screenings for breast and cervical cancers respectively. Similarly, a smaller study using 1,922 respondents from the Tennessee BRFSS for 2001 and 2003 found more urban than rural women received a mammogram in the previous two years (78.3%, 95%CI=75.9-80.7 vs. 71.3%, 95%CI=67.4-75.2).20 After adjusting for demographics, insurance status and having a health care provider, however, rural residence status was no longer significant.

### Summary

Immunization rates appear to be comparable in rural vs. urban areas; however, given that there were only two studies and that both relied on data 10 years old, our confidence in this finding while moderate, remains provisional.

The one study of prenatal care suggested no rural-urban difference; however, given the study design, the regional nature of the sample and the absence of confirmatory findings, our confidence in the evidence base is low.

All studies examining cancer screening rates found rural-urban differences. The primary difference among the studies was that in some of them, the rural-urban difference disappeared once access factors (e.g., income, availability of physicians, insurance status) were controlled, while in others the differences remained significant albeit of a smaller magnitude. This suggests that rural-urban differences in cancer screening rates are at least partially due to differences in health care access.

Of note, screening rates are not uniformly lower across rural areas. For example, a study looking at rates of mammography in randomly selected Rural Health Clinics nationally found triple the rate of screening in the Middle third of the country compared to that in the Western third of the country (OR=3.75, 95%CI=1.43-9.87).31 Studies using national databases, therefore, may overlook actual rural-urban differences by pooling across regions.

Hospitalizations associated with ACSCs are, at best, indirect measures of health care quality and/or access. Of the two studies examining hospitalization rates for ACSCs, we had greater confidence in the study that sampled from eight states and in which a higher rate of hospitalization for these conditions was found in rural areas. That the presence of federally qualified Rural Health Clinics or Community Health Centers have been found in other studies to diminish the rates of ACSC hospital admissions,32 suggests that such admissions may be related to the availability of health care resources. Still, given the limited evidence base, this can only be viewed as provisional.

## CANCER CARE

(Table 4 and Appendix C, Table 3)

Table 4 Confidence Scores for Cancer Care Studies

Study | Shugarman 2008^33^ | Loberiza 2009^34^ | Elliott 2004^35^ | Paquette 2007^38^ | Higginbotham 2001^37^ | Chirumbole 2009^36^ | Schootman 1999^25^ | Kinney 2006^24^ | Sankaranarayanan 2009^40^ | McLafferty 2009^39^ | Schootman 2001^42^ | McLaughlin 2009^41^
Internal Validity | G | F | F | F | F | F | G | G | G | G/F | F | F
Sampling Method/Bias | G | F | G | G | G | G | G | G | G | G | G | G
Predictors/Confounders | G | F | G | F | F | F | G | G | G | G/F | F | G
Outcomes (clarity of measurement) | G | G | F | G | G | F | G | G | G | G | G | F
Statistical Methods | G | G | G | G | F | F | G | G | G | G | G | G
External Validity | F | F | F | F | F | F | F | G | G/F | F | F | F
Use of proxy variables or aggregate measures | G | G | G/F | G | G | F | G | G | G | F | F | G
Representativeness of sample | F | F/P | G | F | G | G | G | G | G | G | G | F/P
Study design appropriate for the research question? | G | G | F | G | F | F | F | F | G/F | G | G | G
Overall Confidence Score | M | M/L | M/L | M | M | L | M | M | H/M | M | M | M/L

Comparisons of rural and urban health care for cancer have focused on variation in staging, mortality, and quality of care. There were 12 studies comparing urban and rural cancer care. Three studies examined mortality.25,33,34 Nine studies examined cancer stage at the time of diagnosis,24,25,33,35-40 three studies examined the relationship between screening and disease progression,25,35,37 and five looked at treatment quality.33-35,41,42

Of the three studies of mortality, two were of regional samples and the one national study used a sample of people 65 years and older. Using the Iowa Surveillance, Epidemiology, and End Results (SEER) database for 1991-1995 and the BFRSS database for 1996-1997, mortality among breast and cervical cancer patients was examined.25 No differences in age adjusted mortality rates for cervical and breast cancer were found between rural and urban women. Similarly, using the national SEER database and the Medicare Claims database from 1995 and 1999, patients over 65 years with lung cancer were identified and service utilization, stage of illness at presentation and mortality rates were compared across four levels of rurality (N=26,073).33 As in the Iowa study, no differences were seen in overall survival between rural and urban areas either before or after adjustments. Factors that were predictive of mortality were patient demographics, receipt of radiation for those with stage II and IV disease, and the number of subspecialists per 10,000 residents 65 years and older. Both the odds of radiation receipt and the supply of subspecialists were lower in rural areas (radiation 47.0% urban vs. 43.2% rural, trend only; subspecialists: urban 10.6 ±7.6 per 10,000 residents vs. most rural 1.2 ± 3.3 per 10,000, p<0.01).

Mortality was also evaluated in a cohort of patients with lymphoma diagnoses who were registered in the Nebraska Medical Center Oncology Database.34 Overall survival rates were lower for those rural residents who were treated by community providers as compared to either urban residents or rural residents treated by university affiliated providers (5 year survival rate 51% vs. 59-66%; p<0.001), suggesting that community providers in rural areas had less expertise. However, because of the nature of the sample used, this finding may not be generalizeable.

Four studies examined differences in rates of diagnostic staging at the time of initial cancer presentation.33,35,37,38 Three studies found differences between rural and urban areas in the odds of having an incident cancer staged, whereas one national study of lung cancer patients 65 years and older did not find differential odds between rural and urban areas.33 A comparison of 1,105 urban residents and 1,463 rural residents from 18 rural communities surrounding Lake Superior with incident cancer between 1992-1997,^35^ found that rural cancer patients were less likely to have breast (60% vs. 83%), prostate (41% v. 60%) or non-small cell lung cancers (82% vs. 90%) staged at the time of initial diagnosis than urban residents. No differences were found in rate of staging for prostate or small cell lung cancers. Examination of 9,685 new cancer cases recorded in the Mississippi State Department of Health Central Cancer Registry in 1996 found that rural residents had significantly lower odds of having their lung, colorectal, breast or prostate cancers staged at the time of diagnosis (OR=0.83)37. This rural disadvantage was notably more pronounced for women (OR=0.75) and for African Americans (OR=0.73). Controlling for race and gender, rural white males were less likely to have their prostate cancer staged than were urban white males (OR=0.70). Finally, a national study of lung and colorectal cancer (CRC) patients found decreased odds of cancer staging at the time of diagnosis among rural residents.38 In a study of 129,811 colorectal cancer patients and 161,479 lung cancer patients registered in the SEER database between 2000-2003, rural patients were less likely to have had their cancer staged for both lung (14% vs. 9%) and colorectal (9% vs. 6%) cancers.38 Taken together, the data suggest differences between rural and urban residents in the odds of having unstaged disease. Moreover, the lower rate of incident cancer staging at the time of presentation may vary by race, geographic location, type of cancer and age of the patient.

Studies that examined stage of disease progression at the time of diagnosis used this outcome so as to infer differences in screening rates and/or treatment access not captured in most national and state databases. For example, examination of the rate of in situ vs. invasive breast and cervical cancers recorded in the Iowa SEER database between 1991-1995 showed that women who were from more urban areas had higher age-adjusted rates of in situ breast cancer (47.7 vs. 37.3 per 100,000) and lower rates of invasive cervical cancer (7.3 vs. 9.3 per 100,000), both of which were interpreted as indicating underutilization of screening in rural areas.25 Similarly, among 2,568 cancer patients in the Lake Superior area study who were staged at the time of diagnosis, rural residents with breast, colorectal, and non-small cell lung cancers were more likely to present at later stages of disease progression than urban residents with those conditions.35 Staging differences were not noted for prostate or small cell lung cancers, however. The Mississippi study also found that rural residents were more likely to present with regional or distant metastatic disease (vs. local) compared to urban residents when cancer types were considered collectively (X^2^=8.4, df=2, p<0.05).37 Comparisons within cancer types in the Mississippi study found that differences between rural and urban residents in the risk for more advanced disease was significant only for lung cancer (X^2^=12.3, p<0.005).37

In contrast to these findings, several studies reported no rural-urban differences or reported an urban disadvantage, and only one of them received a low confidence score.36 For example, the national study of Medicare beneficiaries 65 years and older by Shugarman (2008),33 found no differences between urban and rural areas in the stage of lung cancer at the time of diagnosis, nor did a case-control study of CRC in North Carolina.24 A large national study of colorectal (n=129,811) and lung (n=161,479) cancers using the SEER database compared the odds of late stage disease presentation between the RUCC-defined highly urban and most rural areas (population less than 20,000).38 Relative to the rural areas, urban residence was associated with a small but significantly increased likelihood of stage IV disease for both colorectal (17.9% rural vs. 18.5% urban) and lung (41.2% rural vs. 42.9% urban) cancers after controlling for race, age, median county income and gender. A large study using a multi-level modeling approach to examine the odds of late stage initial presentations of breast, colorectal, lung, and prostate cancers among over 140,000 patients in the Illinois State Cancer Registry who developed cancer between 1998-2002 also found that urban residents were more likely to present with later stage disease for all four cancer types.39

In the Illinois study,39 disparities between urban and rural areas for prostate cancer were eliminated when the model included the patient factors of race and age. For colorectal cancer, the urban disadvantage partially disappeared in the model including patient age and race (B= -0.156, p<0.05 for the most rural) and almost completely disappeared in the model including income and access (B= -0.085, p>0.05 for the most rural). This suggests that distance from a healthcare provider, being young and black were risk factors for later stage of presentation for this illness. Only residence in large towns was associated with lower odds for later stage disease presentation (B= -0.198, p<0.05). For breast cancer, those who were in the most rural areas were equally likely as those in metropolitan Chicago to present with late stage disease (B= - 0.032, p >0.05) and, similar to colorectal cancer, the greatest advantage was for residents of large towns (B= -0.167, p<0.05). Rural areas were comparable to urban areas once age and race were included in the model. Only lung cancer showed a clear urban disadvantage in each model, the greatest advantage being for those residents who were diagnosed in large towns (B= -0.431, p<0.05), a finding similar to that for breast and colorectal cancers.

The advantage for large rural towns in the Illinois study was also found in a well designed study of cancer patients in Nebraska. Examination of the stage of cancer at the time of diagnosis among 5,521 incident colorectal cancers in Nebraska between 1998-2003 found that residents from micropolitan communities (i.e., counties with an urban cluster of 10,000 to 49,999 people) were more likely to present with CRC at earlier stages of disease than residents from more rural or more urban areas in both adjusted and unadjusted analyses (OR=1.22, 95%CI=1.05, 1.42).40

There were very few studies examining the quality of cancer care and those that did suggest that there may be lower quality care in rural areas. Elliott (2004) reported that rural treatment of cancer was found to be of lower quality in the Great Lakes region across cancer types in terms of initial management, clinical trial participation and post-treatment surveillance; however, scores derived to measure these variables were not independently validated.35 In a study of almost 7,000 women treated for breast cancer from 1991-1996 in the national SEER database, younger women with newly diagnosed ductal carcinoma in situ had reduced odds of therapeutic radiation receipt if they lived in a rural area (OR=0.38).42 While radiation receipt among younger women was not related to availability of therapeutic radiation in the patient's county, for older women more distant access to a therapeutic radiation site was associated with reduced odds of radiation receipt (OR=0.48). A similar finding was observed in a national study of Medicare beneficiaries over 65 years, where fewer of those living in rural areas received radiation (most urban 46.8% vs most rural 43.2%).33

Two studies observed differences in the availability of cutting edge treatments, but since both studies were rated with fairly low Confidence Scores the findings should only be viewed as suggestive and worthy of further study. A study of 461 women with estrogen sensitive breast cancers listed in the North Carolina Central Cancer Registry and who were also Medicaid enrollees between 2000-2004 examined the odds of ever receiving a prescription for an aromatase inhibitor (vs. Tamoxifen only). Rural residents were less likely than urban patients to have received a prescription for an aromatase inhibitor (OR=0.54).41 The quality of lymphoma treatment was found to be lagging in rural areas, but only if the provider was not university affiliated.34 While this suggests that rural community based treatment for lymphoma is of lower quality, our confidence in the generalizability of these findings is relatively low.

### Summary

The evidence for differences in cancer-related health outcomes related to place of residence is relatively weak for most outcomes. Many of the studies used data that were at least 10 years old. Given the rapidly evolving nature of oncologic care, this is a significant limitation.

There were no consistent rural-urban differences in mortality or in the stage of illness at the time of initial presentation. Greater consistency was noted in the odds of unstaged disease, with rural residents less likely to have their cancer staged at the time of initial presentation. Interpretation of this finding is complicated by two factors, however. First, studies categorized patients by residence rather than by point of care and rural patients are more likely to pursue treatment for conditions such as cancer in urban areas.43 Rural providers may not pursue diagnostic procedures necessary to stage cancer if the patient intends to pursue treatment elsewhere. Second, the evidence base may be subject to a reporting bias since the odds of cancer staging were never the primary focus of the studies reviewed and studies that did not find a difference may not have reported a null finding.

It must be noted that patients in rural areas are not homogeneous, and barriers impeding screening of and treatment for cancer vary within both urban and rural populations. Depending on the compositions of the rural and urban samples being compared, age differences, income factors and racial/ethnic disparities may underlie some rural-urban differences when they emerge. For example, the large percentage of low income blacks in Chicago relative to the more rural areas in Illinois likely contributed to urban disadvantage in the odds of later stage of cancer at initial presentation. Similarly, older breast cancer patients may be more affected by distance to care than younger patients.

Finally, studies looking at rural-urban differences in quality of care were few and methodologically problematic given either a lack of association with specific treatment guidelines or that treatment guidelines changed during the course of the study (e.g., McLaughlin, 2009).41

## DIABETES/END STAGE RENAL DISEASE

(Table 5 and Appendix C, Table 4)

Table 5 Confidence Scores for Diabetes and End-Stage Renal Disease Studies

Study | Andrus 2004^47^ | Weingarten 2006^41^ | Krisha 2010^45^ | Rosenblatt 2001^50^ | Morden 2010^49^ | Koopman 2006^48^ | Ward 2009^46^ | O'Hare 2006^44^
Internal Validity | F | F | G | F | G | F | F | G
Sampling Method/Bias | F | F | G | F | G | G | F | G
Predictors/Confounders | P | P | G | F | G | G | F | G
Outcomes | G | G | G | F | G | G | F | G
Statistical Methods | P | G | G | F | G | F | P | G
External Validity | F/P | F | F | F | F | F | F | G
Use of proxy variables or aggregate measures | F | F | G | G | G | G | F | G
Representativeness of sample (size, composition) | P | P | F | F | G | F | F | G
Is the study design appropriate for the research question? | F | F | F | G | F | G | F | G
Overall Confidence Score | VL | L | H/M | M | H/M | M | L | H

Only three studies (all cross-sectional) examined potential differences in health outcomes between urban and rural residents for diabetes or kidney disease.44-46 One moderate to high quality study relied on patient self-report to assess complications of diabetes in a national sample,45 while a low quality examined the incidence of diabetes-related end-stage renal disease.46 The third study, of high quality, examined mortality rates between urban and rural patients receiving dialysis.44 There were six studies (also all cross-sectional) examining differences in measures of care for diabetes (e.g., concordance with American Diabetes Association [ADA] guidelines). Two were of low quality, two were of moderate quality, and two were of moderate to high quality. The smallest study compared two sites,47 two national studies reported no difference between rural and urban areas,48,49 and another large national study reported a mixed effect of residence category in that some outcome measures were more favorable for those in rural areas whereas others were more favorable for those in urban areas.45 A fifth study in Washington State found better quality of care measures in large towns than in either urban or more rural areas.50 The sixth study of adherence to ADA guideline recommendations was a national study that found rural disparities, but only in some parts of the country, and rural advantage in others.51

In a study by Morden et al. (2010),49 quality indicators of eye exams, foot exams, LDL levels, blood pressure and hemoglobin A1c (HbA1c) levels were assessed among 11,688 veterans with diabetes in 2005. No differences were found in quality indicators between highly rural and urban RUCA categories. Koopman (2006), using the National Health and Nutrition Examination Survey from 1988-1994 and rural or urban classification based on metropolitan statistical areas, found that urban Hispanics had higher odds of their diabetes not being detected relative to urban whites (3.7% vs. 2.3%), rural whites (2.8%), and rural Hispanics (2.7%; p<0.05).45 Urban Hispanics were also more likely than the other groups to report a lack of usual source of health care (11.4% vs. 1.8% urban whites, 6.5% rural whites, and 5.1% rural Hispanics; p<0.01). In multivariate analyses, urban vs. rural primary residence was not associated with the odds of diabetes being detected once demographic and health care utilization were controlled. This further supports the association between non-detection of diabetes and limited contact with health care providers. In addition, rural Hispanics more frequently had uncontrolled BP relative to urban Hispanics (OR=1.5, 95%CI=0.94-3.45) or either group of whites (p<0.01), but they were not significantly different from either group of whites in multivariate analyses controlling for demographic, access and some health factors. There were no group differences in glycemic or control or lipid levels.

A rural disadvantage was reported in a very small study in Alabama comparing patients in one “rural” family practice clinic (n=78) and one “urban” internal medicine clinic (n=109) with respect to HbA1c levels, eye exams, foot exams, lipid profiles, and microalbuminuria tests.47 Urban and rural were not defined, and given the local nature of the study and the methodologic issues, our confidence in this finding is very low.

A much larger and better designed study comparing compliance with ADA guidelines for HbA1c levels, eye exams, and foot exams in two national databases reported that rural residents with diabetes received both more and less guideline care depending on the outcome and database used.45 Although the directions of effects were the same in both databases, they were only significantly different in the larger database. Slightly more rural residents, defined as those living in non-metropolitan statistical areas, received a quarterly HbA1c level (OR=1.16), but this difference was no longer significant after adjustments (i.e., race, region of the country, insurance coverage, and having a personal physician). Differences that remained significant even after adjustment were decreased odds among rural diabetics of having a dilated eye exam (OR=0.88) or foot exam (OR=0.85) or receiving diabetes education (OR=0.83). Inconsistent evidence for rural-urban differences in diabetes care was reported in a study of older Medicare patients in Washington State.50 Urban residents with diabetes were equally as likely as rural residents to get eye exams, but they were more likely than rural residents (defined based on RUCA with 4 rural subgroups) to get an HbA1c check (55.6% vs. 52.2%) and a cholesterol screen (66.6% vs. 63.2%). After adjustments, residents living in large remote rural towns were the most likely to have had the tests. Importantly, rural residents were only less likely to get the assessments if they had not seen an endocrinologist in the prior year.50 That is, specialty consultation, much more common among urban residents, was a primary determinant as to whether patients received the guideline assessments.

Some of the inconsistency across studies may be due to differences between rural and urban areas in the rate of adherence to guideline recommended tests across geographic regions of the country. For example, in an examination of the geographic distribution of diabetic patients receiving a composite measure of guideline tests (i.e., lipid levels, HbA1c levels, and eye exams), Weingarten et al. (2006), found that rural residents (categorized as rural or semi-rural) were actually more likely to receive the tests than urban residents depending on in which region of the country they lived.51 Because the study relied on aggregate measures, however, this finding should be considered only tentative.

One of the many deleterious consequences of poorly controlled diabetes is end-stage renal disease (ESRD). Ward (2009) compared the rural and urban zip codes of 18,377 diabetic patients in California for the odds of ESRD attributable to diabetes.46 There was only a trend for a decreased likelihood of ESRD among rural patients (beta=-0.035, p<0.06). However, because the model was adjusted for factors associated with access and poor illness control (i.e., insurance status and number of hospitalizations due to hyperglycemic complications), it may be that one of these factors underlies the differences associated with rural vs. urban residence. That patients from health professional shortage areas were actually less likely to have ESRD, may reflect this problem with their model. Because bivariate results were not reported for this parameter, we could not assess potential problems with the statistical model used and rated our confidence in the finding as low.

In an analysis of treatment for 552,279 patients with ESRD who initiated dialysis between 1995-2002, the impact of rural vs. urban residence varied by race and ethnicity.44 There were no significant differences between urban and rural areas in types of treatment other than that rural areas (including large rural, small rural, and remote) were more likely to use peritoneal dialysis. When target hematocrit levels were the outcome, there were no significant differences between urban and rural areas. Target urea reduction ratios were slightly more likely to be reached by rural than urban sites (small rural 92.9% vs. 91.2% urban). Mortality and transplant rates showed a more complex picture, however. Relative to urban Hispanic patients, rural Hispanic patients had elevated mortality rates both before (OR=1.25, 95%CI=1.14-1.36) and after adjustment (OR=1.11, 95%CI=1.01-1.22). Rural white non-Hispanics and blacks had lower mortality than urban white non-Hispanics and blacks, respectively, but only after adjustment. Transplant rates were lowest among black patients regardless of where they lived, with residents of small rural areas more disadvantaged than residents of urban areas (OR=0.89, 95%CI=0.82-0.96). In contrast, rural Native Americans living in remote areas were actually more likely than Native Americans living in urban areas to get a transplant (OR=1.27, 95%CI=1.01-1.59). A similar rural advantage was evident for non-Hispanic whites (OR=1.11, 95%CI=1.06-1.16).

### Summary

There were no consistent differences between rural and urban areas in diabetes treatment quality measures, and two of the largest, moderate to high quality studies found no differences. Whether rural-urban differences in diabetes care varies across regions of the country requires further exploration.51 For all patients, having access to a physician, and possibly an endocrinologist, may increase the odds of both illness detection and adherence to treatment guidelines. The increased use of Rural Health Clinics in underserved areas has greatly improved treatment access and, consequently, adherence to treatment guidelines.52

There was also little evidence for a disparity between rural and urban patients with diabetes in terms of diabetes complications or the prevalence of ESRD. Once a patient had ESRD, racial differences clearly affected outcomes, and this variation across race/ethnicity groups interacted with rural vs. urban residential categories. For example, a high quality study reported that blacks with ESRD had lower transplant rates regardless of where they lived, but were more disadvantaged in rural areas.44 In contrast, rural Native Americans were actually more likely than their urban counterparts to receive a transplant.44

## CARDIOVASCULAR DISEASE

(Table 6 and Appendix C, Table 5)

Table 6 Confidence Scores for Cardiovascular Disease Studies

Study | Morden 2010^49^ | King 2006^54^ | Colleran 2007^55^ | Hicks 2010^53^ | Dellasega 1999^56^
Internal Validity | G | P | F | F | P
Sampling Method/Bias | G | P | G | F | P
Predictors/Confounders | G | G | F | F | F
Outcomes | G | P | G | G | F
Statistical Methods | G | F | F/P | G | P
External Validity | F | P | F | F | P
Use of proxy variables or aggregate measures | G | P | F | G | F
Representativeness of sample | G | P | P | F | P
Study design appropriate for the research question? | F | F | G | F | P
Overall Confidence Score | H/M | VL | L | M | VL

Only five studies examined outpatient management of cardiovascular disease, and two of these were smaller regional studies. The largest study, and the only one for which we had at least a moderate to high Confidence Score, was done by Morden et al., (2010) on 23,780 veterans with hypertension, about one-third of whom also had a mental disorder.49 No differences in blood pressure (BP) control were found across three RUCA categories.

A Colorado study compared quality of care for hypertension among 780 rural and urban patients with diabetes from 26 primary care sites.53 The study relied on provider post-appointment surveys. They found that rural patients had lower systolic and diastolic BP, but that urban providers were more likely to take action than rural providers if the patient's BP were poorly controlled (39.1% vs. 27.5%, p<0.02). However, of the factors that predicted whether action was taken at a given medical visit, the number of prescribed medications and whether the patient's BP was at or near goal were the only significant predictors, possibly reflecting differences in subsample characteristics. Of note, number of prescribed medications was significantly associated with rural residence (e.g., 39% of rural residents were taking 8 or more medications, whereas only 28% of urban residents took as many; p<0.025).

The remaining studies were given fairly low Confidence Scores, and so shall be reviewed only briefly. In a study by King (2006), rural site of health care was associated with better BP control in a chart review study looking at 300 people from three separate practices in South Carolina (OR=0.3, 95%CI=0.16-0.55).54 We rated this study as having lower quality because of the small non-random sample, lack of control of within site clustering, and use of chart indications of adherence. A second regional study, comparing one urban with one rural site in New Mexico examined differences in treatment via chart review of 200 patients, 100 with cardiovascular disease and 100 without.55 They found that patients treated in the urban, university associated center were much more likely to receive beta-blockers or calcium channel blockers, antiplatelet therapy, and statins, and that urban patients were better at attaining BP goals (53% vs. 37%, p=0.02). LDL goals, on the other hand, were comparable in rural and urban areas (51% vs. 57%, ns). Confidence in this study's findings were considered to be low due to the sampling method, statistical approach, and variable outcome measures.

Finally, a series of case reports examined change in medication regimens in 32 elderly cardiac patients post-discharge.56 Urban cardiac patients reported greater fluctuations in medication regimen, as suggested by the number of changes in the types of drug used after discharge compared to rural cardiac patients; however, the urban cardiac patients had worse outcomes than the rural patients despite comparable levels of cardiac disease.

### Summary

Three of the five studies reviewed were quite small, and only one study had a higher Confidence Score. That study, conducted on veterans, found no differences between rural and urban patients in control of hypertension. The Colorado study found different degrees of blood pressure control between urban and rural residents, but no differences in quality of care. However, that study consisted of patients with diabetes and had some significant flaws that compromised the reliability of the findings. The remaining studies were not of sufficient quality to draw conclusions beyond the clinics from which their samples were drawn.

## HIV/AIDS

(Table 7 and Appendix C, Table 6)

Table 7 Confidence Scores for HIV/AIDS Studies

Study | Whyte 1992^57^ | Napravnik 2006^59^ | Schur 2002^60^ | Cohn 2001^58^
Internal Validity | F | G/F | F | G
Sampling Method/Bias | G | F | G/F | G
Predictors/Confounders | P | G | G | G
Outcomes | G | G | F | G
Statistical Methods | F | G | G | G
External Validity | P | F | F | G/F
Use of proxy variables or aggregate measures | F | F | F | G
Representativeness of sample | P | F | F | G
Study design appropriate for the research question? | P | G | F | F
Overall Confidence Score | VL | M | M | H/M

There were four papers that reported rural-urban differences in HIV/AIDS patients.57-60

In a study of 308 women from Georgia diagnosed with AIDS by 1990, non-metropolitan residence was associated with a shorter median survival time (296 days vs. 400 days for urban residence) and a lower odds of surviving 90 days (0.84 urban vs. 0.69 non-metropolitan).57 Our confidence in the study is very low, however, given significant methodologic problems and the use of data that covered cases diagnosed over 20 years ago.

The frequency of visits per year did not differ between urban and rural residents in either adjusted or unadjusted analyses of a large observational cohort study of HIV patients in North Carolina.59 However, all patients received care at the University of North Carolina HIV Outpatient Clinic, suggesting that distance to clinic was not a significant barrier to care. Relatedly, a national study using the HIV Cost and Services Utilization Study (HCSUS) from 1996 found that nearly three-quarters of rural HIV patients receive their HIV-related care in urban areas.60 Only older age was associated with receiving HIV-related care in a rural setting. In contrast to the North Carolina study, nearly one-third who received their care in urban settings reported that the distance deterred them from needed clinic appointments; however, actual number of clinic appointments was not assessed. Using the same dataset, Cohn (2001) found that rural HIV-related care was more likely to be of lower quality than urban care. Specifically, they found that 73% of urban residents received highly active antiretroviral therapy (HAART) vs. only 57% of rural residents (p<0.001).58 After adjusting for CD4 counts and the covariates (see table), urban patients had a three-fold higher odds of receiving HAART than rural patients. Moreover, whereas 75% of urban patient received prophylactic medication for pneumocystis carinii pneumonia, only 60% of rural residents did (p<0.007). Although not directly related to treatment variables, these differences may be due to the fact that 38% of rural patients received care from providers with little experience treating HIV patients compared to only 3% of urban residents.

### Summary

The very sparse data on the treatment of HIV/AIDS suggests that rural residents might not receive care comparable to that received by HIV infected residents living in urban areas if they receive care locally rather than travel to specialty HIV clinics in urban areas. However, no firm conclusions can be drawn from this minimal evidence base. A more recent assessment of the quality of HIV care is warranted given that diffusion of knowledge regarding treatment standards for HIV/AIDS may have occurred in the intervening period.

## NEUROLOGIC CONDITIONS

(Table 8 and Appendix C, Table 7)

Table 8 Confidence Scores for Neurologic Conditions Studies

Study | Buchanan 2006a61 | Buchanan 2006b62 | Buchanan 2006c63 | Schootman 1999^64^ | Johnstone 2002^65^ | Wilson 2009^66^
Internal Validity | F | F/P | F/P | F | G | G
Sampling Method/Bias | P | P | P | G | G | G
Predictors/Confounders | G | G | G | F | G | G
Outcomes | F | F | F | F | G | G
Statistical Methods | P | P | P | F | G | G
External Validity | F/P | F/P | F/P | F | G/F | G/F
Use of proxy variables or aggregate measures | F | F | F | F | F | F
Representativeness of sample | P | P | P | F | G | G
Study design appropriate for the research question? | F | P | P | F | G | G
Overall Confidence Score | L/VL | VL | VL | L | H/M | H/M

There were only three studies that examined urban/rural differences in health care for patients with multiple sclerosis (MS), and all three of them were from the same research group and were based on the same dataset. The studies were based on a survey of national MS Society members, with sampling stratified to achieve 500 MS patients in each of three population density categories: urban, within 50 miles of urban area, and more than 50 miles. Their overall response rate was a low 31%, and several aspects of the methodology resulted in our giving all three studies low Confidence Scores.61-63 In bivariate analyses, more MS patients in rural areas had a primary progressive form of MS, but fewer reported that they were being treated with disease modifying medications (urban 64%, adjacent rural 57%, remote rural 55%).61 More MS patients in urban areas saw a neurologist in the previous year (urban 75.4%, adjacent rural 71%, remote rural 66.5%) and more patients in remote and adjacent rural areas indicated that they had wanted to have seen a neurologist in the previous year but did not do so (urban 9.4%, adjacent rural 18.9%, remote rural 26.9%).62 Finally, the primary reason reported for not seeking treatment was a lack of availability of mental health providers (urban 5%, adjacent rural 33%, and 13% remote rural).63

There were only two studies that focused on services for those who incurred a traumatic brain injury (TBI).64,65

A survey of 292 residents with TBI 12-18 months previously, in the Iowa Central Registry for Brain and Spinal Cord Injuries in 1998, examined self-rated health and dependence on others.64 There were no differences between rural vs. urban areas in the association between perceived need for care and actual receipt of services; however, the authors did not examine the odds of service receipt in a multivariate model, and we rated this study with a low Confidence Score.

Two studies examined the availability of health professionals who provide the interdisciplinary care needed by those who had TBIs. A survey of health providers in Missouri in 1999 found that although nearly one-third of state residents live in rural areas, much lower percentages of all provider types related to the treatment of patients with TBIs (e.g., physiatrists, other physicians, rehab therapists, mental health providers) worked in rural areas.65 A similar pattern was found in a nationwide study of numbers of rehabilitation therapists (physical therapists, occupational therapists, and speech-language pathologists) in counties or "county sets" in most of the contiguous United States between 1980-2000.^66^ Fewer rehabilitation therapists per 100,000 residents were found in primary care health professional shortage areas. Although the number of all three types of rehabilitation therapists increased in both urban and rural county sets during the 20 year time period, the difference in the ratio of therapists per 100,000 residents remained significantly different between urban and rural areas (urban: rural rates per 100,000 for physical therapists 50.9: 35.5, occupational therapists 24.7: 15.3, and speech pathologists 35.0: 29.5).

### Summary

Findings from the three studies of rural treatment for MS, all based on the same dataset, were inconclusive given several methodologic problems with the research design, measures and analyses.

There was only one study that looked at outcomes for patients with a history of TBI in rural vs. urban settings of Iowa, but we had little confidence in the findings of that study. Two studies examining the availability of rehabilitation specialists found a paucity of such providers in many rural areas relative to urban areas. Significantly more research should be done on the course of recovery of rural TBI patients after their acute treatment, and to ascertain what types of services they receive by commuting to urban areas, what services are precluded by limited provider availability and/or travel distance, and what the impact of provider availability is on health outcomes.

## MENTAL HEALTH

(Table 9 and Appendix C, Table 8)

Table 9 Confidence Scores for Mental Health Studies

Study | Gibbons 2005^67^ | Fiske 2005^68^ | Farrell 1996^72^ | Fischer 2008^73^ | Mohamed 2009^75^ | Rost & Owen 1998^76^ | Rost 1999^77^ | Fortney 1999^74^ | Fortney 2007^70^ | Fortney 2009^71^ | Rost & Zhang 1998^69^ | Rost 2007^78^ | Elhai 2004^79^ | Booth 2000^80^ | Grant 1996^81^ | Metsch 1999^82^ | Fortney 1995^84^ | Robertson 1997^83^ | Petterson 2003^85^ | Petterson 2009^86^ | Hauenstein 2006^87^ | Wang 2005^88^
Internal Validity | F | F | F | F | F | F | G | G | G/F | G/F | G | F | F | G | G/F | F | G | F | G/F | G/F | G/F | G
Sampling Method/Bias | G | G | G | G | G | G | G | G | G | G | G | F | G | G | G | F | G | G | G | G | G | G
Predictors/Confounders | F | F | P | F | G | G | G | G | F | F | G | G | P | G | G/F | G | G | F | G | G | G | G
Outcomes | G | G | G | F | F | F | G | F | G | G | G | F | G | G | G | G | G | F | F | F | F | G
Statistical Methods | G | F | F | G | F | G | G | G | G | G | G | G/F | F | G | G | F | G | F | G | G | G | G
External Validity | F/P | F/P | F | F | F | F | F | F | F | F | F | F | P | G/F | F | F | F | F | F | F | F | F
Use of proxy variables or aggregate measures | P | P | G | F | G | G | F | G | F | F | F | F | G | F | F/P | G | F | F | F | F | F | G
Representativeness of sample | G | G | G | F | G | P | G/F | F/P | G | G | G/F | F | F/P | G | G | P | G | G/F | G | G | G | F
Study design appropriate for the research question? | F | F | F | G | F | F | G | F | F | F | G | F/P | P | G | G/F | F | F | F/P | G | G | G | G
Overall Confidence Score | L | L | M | M | M | L | M | M/L | M/L | M/L | M | L | VL | H/M | M | M/L | M | L | M | M | M | H/M

There were three studies that compared suicide rates and medication use between rural and urban areas,67-69 two studies that examined the odds of hospitalization,70,71 five papers that addressed MH service access among rural residents with severe mental illness,72-76 three studies that examined rural-urban differences in treatment of mood disorders,69,77,78 one study examining PTSD,79 five studies that examined receipt of alcohol/drug treatment,80-84 and four papers that examined whether subgroups of rural residents were less likely to get mental health treatment.85-88

A large national study of suicide completers found an association between suicide and antidepressant prescription rates.67 In rural areas, the suicide rates were higher than in urban areas (17.14 per 100,000 in the most rural vs. 11.51 per 100,000 in the most urban). Within these rural areas, there were fewer prescriptions for antidepressants and, of those that were written, a higher proportion of them were for the older tricyclic antidepressants (ratios of tricyclics vs. newer antidepressants were 1:1 in rural vs. 1:2 in urban). Only prescriptions for non-tricyclic antidepressants were associated with reduced suicide rates. A second study examining suicide rates among 41 county clusters in California from 1993-2001, found similar elevations in suicide rates among rural counties, but no association between suicide rates and the availability of either health care providers or physicians.68 Although suggestive, these studies use only aggregate measures and limited control for confounders, resulting in lower Confidence Scores. One study that followed 470 depressed people in Arkansas found no difference in the odds or quality of depression treatment between rural and urban residents, but did find an elevated rate of suicide attempts among those in rural areas.69

Both studies that examined hospitalization rates per county for major mental illnesses used the 2000 Health Care Cost and Utilization Project database for 14 states.70,71 Both studies reported similar findings – that rural areas had lower hospitalization rates. Specifically, hospitalization rates for schizophrenia were greatest in the most urban areas relative to all others (p<0.05).71 Similarly, hospitalizations for depression were lower in rural vs. more urban areas (e.g., 49% lower in the most rural counties, p<0.05).70 No relationship was found between provider availability and hospitalization rates for schizophrenia, but positive relationships were found between availability of physicians and hospitals and hospitalization rates for depression (p<0.05); however, there was no relationship between hospitalization rates and availability of psychiatrists.71 Both studies examined environmental predictors of hospitalization rates and found that factors associated with urban living (e.g., housing stress) were predictive of higher rates, where as rural factors (e.g., farm-based economies) appeared to be protective. Because the base rates of mental illness in the counties studied were not known a priori and because both studies relied on aggregate measures, it cannot be determined from these studies whether urban environmental factors are conducive to the development or exacerbation of mental illness (or highly rural areas protective), or whether mentally ill people are more likely to migrate to urban areas. Consequently, our Confidence Scores are lower for these studies.

There were five articles that addressed accessibility of MH services for rural residents with severe mental illness, one of which was an examination of the VA's mental health intensive case management program (MHICM). Three of these focused on whether rural residents with serious mental illness had difficulty accessing needed services, one examined whether travel time affected the number of mental health treatment appointments, whereas the fifth examined access within the context of continuity of care.

Rost et al. (1998) screened 11,078 adults in Arkansas for mental illness and compared rural-urban differences in a very small subsample with bipolar disorder (29 rural and 24 urban residents) on service utilization and outcomes.46 Rural residents were much more likely to be seen only in a general medical setting (OR=22.1, 95%CI=2.5-198.3), to have needed acute medical or mental health care (OR=5.8, 95%CI=0.8-40.7), and to have experienced a manic episode in the year following the baseline assessment (OR=4.0, 95%CI=0.8-20.5). Although the screened sample was large, the resulting small number of those with bipolar disorder resulted in a low Confidence Score rating. The same study produced a larger number of patients with major depression, but only n=106 were included in a study examining the relationship between travel time to a preferred provider, number of depression-related appointments, and the odds of receiving guideline concordant depression treatment.74 Distance from a preferred provider was significantly associated with a reduced number of visits in adjusted analyses (p<0.05). Increased travel time, in turn, was associated with reduced odds of guideline concordant treatment (OR=0.292, CI= 0.087-0.987).

A study of 258 patients with schizophrenia seen in public mental health settings (primarily VA) in Arkansas between 1992-1999, found that rural residence was associated with an increased risk of an irregular vs. regular pattern of mental health service use in adjusted analyses (OR=1.99, 95%CI=1.07-3.71).73 For all patients, comorbid substance abuse increased the odds of infrequent or irregular mental health service use. However, among rural residents, the negative impact of comorbid substance abuse was significant only if the patient did not have contact with their family at least once per week (OR=41.94 for infrequent service use vs. regular MH use among those with minimal family contact). This suggests that the role of family in managing patients with severe mental illness may differ in rural vs. urban areas.

The VA study of the amount and types of care received by 5,221 patients with serious mental illness enrolled in a MHICM program reported that patients in rural areas received fewer types of services than urban patients.75 Although the difference in patient contact between rural and urban residents differed only slightly (though significantly), rural residents were less likely to receive several types of recovery-related services, such as psychotherapy (83% urban vs. 67% isolated rural), substance abuse treatment (35% urban vs. 29% rural town and 12% isolated rural), and rehab services (48% urban vs. 42% rural towns and 27% isolated rural) despite comparable symptomatology. Moreover, rural residents were more likely to be seen by only one person on the treatment team than urban patients. Whether this affected recovery is unclear, as all symptom measures were assessed at the time of program enrollment.

The fourth study focused on the ease of care transition from inpatient to outpatient services for 4,930 patients with serious mental illness who were discharged from Virginia state hospitals in 1992.^72^ Specifically, they found that rural residents had significantly better continuity of care than urban patients in that the community mental health centers associated with outpatient treatment for rural residents were much more likely to have copies of the discharge records (89% rural vs. 76% urban), to have contacted the patient during the hospitalization (58% rural vs. 49% urban), to have made contact with the patient after discharge (82% rural vs. 78% urban), and to have seen the patient for an appointment (79% rural vs. 76% urban). Despite some limitations in rural mental health services for those with serious mental illness, the smaller size of rural community mental health clinics likely contributed to the post-discharge continuity. Of note, there were no differences in a composite of these continuity measures between black and white patients in rural areas, but in urban areas, blacks were clearly disadvantaged. That is, race disparities existed mostly in urban areas.

There were two other studies that used the same dataset that examined rural-urban differences in treatment of bipolar disorder referenced above, and these subsequent studies focused on Arkansans who screened positive for major depression. Examining quality of care and outcomes for the 434 who met criteria for major depression, Rost (1999) reported that there were no rural-urban differences in the odds of outpatient treatment of depression, type of care, odds of care meeting clinical guidelines for acute stage treatment, or adherence to treatment.77 Urban residents were more likely to have been high users of specialty mental health care, with 22% making 23 or more visits during the follow-up year compared to 4% of rural residents (p=0.04). Rural residents, were significantly more likely to be hospitalized for physical problems (OR=3.05, 95%CI=1.23-7.53). In the second paper, the odds of these elevated admissions were really significant only during the first 6 months after baseline, with rural residents having much higher odds of hospitalization for physical (6.1% vs. 0.3%, p<0.01) and mental health (9.8% vs. 1.1%, p<0.05) problems.69

Rural vs. urban hospitalization rates for depressed patients was also examined in a secondary analysis of two separate depression treatment studies, involving 1,455 patients from 11 states.78 As in the Arkansas study, it was found that the odds for hospitalization in a six month follow-up period were greater among rural residents for physical health problems (OR=1.8, 95%CI=1.2-2.8). At 18 months, rural residents had more hospitalizations for mental health problems (OR=2.3, 95%CI=1.0-5.4). Although there were no differences in the rate of outpatient specialty care between urban and rural residents, only about one-third of all patients in the sample indicated that they took antidepressants for at least two of the previous six months. Because of the sampling and other methodologic problems inherent in this study, however, our Confidence Score was low.

Only one very small study examined service use among patients diagnosed with PTSD.79 No significant differences were found in the number of specialty PTSD clinic appointments between 48 urban and 52 rural veterans. The absence of a finding is inconclusive, however, given the inadequate power to detect possible differences and the limited number of confounders included in the analyses.

There were five studies that examined receipt of alcohol/drug treatment. Two studies of moderate to moderately high quality found no rural-urban differences in treatment utilization,80,81 and three of moderate to low quality found greater treatment utilization among residents living in urban areas.82-84

In a Florida study of 2,222 out-of-treatment injection drug users and crack smokers, the rate of drug treatment receipt in the previous 24 months was twice as high for drug users in the urban Miami area than for drug users in the rural Immokalee area (16.3% vs. 4.4%, p<0.001).82 Moreover, those in the urban Miami area who received any treatment were in treatment for twice as long as those treated in the more rural Immokalee area (28.3 weeks vs. 12.1 weeks, p<0.001). Importantly, however, there was a much lower rate in the Immokalee area of unsuccessful attempts at getting treatment (4.9% vs. 10.8%, p<0.001), suggesting that the lower rate of treatment receipt among the rural drug users was at least partially due to differences in treatment seeking. Given the sampling issues, however, the generalizability of this study is limited.

Comparable treatment rates were reported in a lower quality study by Robertson and Donnermeyer (1997),83 who assessed rates of treatment for drug abuse in the 1991 National Household Survey on Drug Abuse. Among the 3,629 subjects included in their study, only 10.8% of the nonmetropolitan-rural respondents received drug treatment and, among those who used illegal drugs in the past 12 months, the rate dropped to 5.6% (vs. 6.6% of the remaining survey respondents). Finally, in a study examining continuity of care for 4,621 veterans discharged from inpatient alcohol treatment programs, rural residence increased the odds of attending an aftercare appointment.84 However, distance to treatment was a significantly greater treatment barrier for rural residents than for urban residents. 84

To better define which rural residents were less likely to utilize mental health care, there were four papers using national samples that examined whether subgroups of rural residents were particularly unlikely or disadvantaged. Using data from two panels of the MEPS between 1996-1998, Petterson (2003) observed that rural residents who received mental health care had fewer visits per calendar year than urban residents (p<0.01), had higher rates of hospitalization (p<0.04), and were more likely to only see a physician for their treatment (p<0.02).85 Rural residents had fewer mental health visits even after adjustment for demographic factors (p<0.01). After adjustments were made for income, insurance and physical health status in addition to demographic variables, the differences between rural and urban residents in mental health care use were only a trend (p<0.1), suggesting that differences in access accounted for much of the observed disparity for rural residents. Importantly, Petterson (2003) noted that urban residents who reported only “fair mental health” were nearly twice as likely as similarly rated rural residents to have sought mental health care (38% vs. 24%, p<0.01) suggesting that rural and urban residents may also differ in perceived need for care. 85

In a separate study, Petterson (2009) used four panels from the same database (representing 1996-2000) to examine whether rural-urban differences observed in the 2003 study were similar across racial/ethnic groups.86 They observed a rural disadvantage for receipt of any mental health treatment among whites, with 9.4% in urban areas having received mental health care but only 7.3% of those in the most rural areas. Both blacks and Hispanics were less likely to receive any mental health care or specialty mental health care regardless of whether they lived in a rural or urban area. However, whereas the difference between blacks and non-Hispanic whites was significant independent of residence urbanicity, the disparity between blacks and whites was greater in urban areas than in rural areas (urban OR=0.41, 95%CI=0.35-0.49; rural OR=0.58, 95%CI=0.35-0.94). The same pattern was seen when only specialty mental health care was considered -- the difference between blacks and whites was significantly different in urban areas, but not in the most rural areas (urban OR=0.43, 95%CI=0.36-0.53; rural OR=0.62, 95%CI=0.28-1.39). Differences between whites and Hispanics follow a similar pattern except that specialty mental health care differed only in urban areas, whereas the receipt of “any mental health care” differed in urban and larger rural areas but not in the most rural areas.

Another study using the same dataset (MEPS from 1996-2000) focused on gender differences in mental health care use between rural and urban residents.87 Women from any geographic area were significantly more likely to have had any mental health treatment or specialty mental health treatment than men (10% vs. 5.8% and 6.3% vs. 3.8%; p<0.01). They found that both men and women in rural areas were less likely to receive specialty mental health services relative to their urban counterparts even after adjustment for demographics, insurance and usual source of care (women urban-rural OR=1.52, men urban-rural OR=1.94; p<0.05).

In examining mental health treatment across disorders, the National Comorbidity Study-Replication study conducted between 2001-2003,^88^ found that urban residents were much more likely to have received mental health services within the previous 12 months than rural residents (urban vs. rural OR=2.1, 95%CI=1.7-2.7), and more likely to have received specialty mental health treatment (urban vs. rural OR=2.2, 95%CI=1.2-4.1). However, treatment adequacy from mental health specialists (but not general medical providers) when it did occur, was found to be lower in urban areas among those who received any mental health treatment (urban vs. rural OR=0.4, 95%CI=0.2-0.8).

### Summary

Many studies of mental health services in rural vs. urban areas focused on specific regions, which may not be generalizable to other parts of the country. Most studies examined differences in service provision and only a few associated any differences that were found with patient outcomes. This limited the conclusions that could be drawn regarding the adequacy of rural vs. urban health care. In those few studies that assessed patient outcomes, no consistent evidence for a rural disadvantage was found. Moreover, while rural residents were found to receive fewer MH services than urban residents in several studies, the clinical impact of this difference was not assessed.

Two studies that focused on the relationship between suicide and mental health care parameters used aggregate (i.e., county) measures for both variables. Although the elevated suicide rates could suggest differences in health care access and/or quality, it is unclear whether the observed association between reduced county mental health care parameters (e.g., new generation antidepressant use) and suicide rate would remain if the individual (vs. the county) were the unit of analysis. One prospective study found elevated suicide rates among depressed rural residents in Arkansas, but the small numbers made it impossible to determine if this were related to differences in mental health care.

Of note, two studies found greater racial disparities in mental health treatment receipt in urban areas. This could reflect a selectively improved access for whites in urban areas or a greater difficulty with access for minorities. Moreover, it also underscores the importance of examining race-rurality interactions, since ignoring such interactions could result in both race and/or rural disparities being attenuated.

## PROCESSES OR STRUCTURE OF CARE

(Table 10 and Appendix C, Tables 9-13)

There were a number of studies that compared various aspects of health care structure or processes between urban and rural health care settings without focusing on either a particular medical or mental health condition or, in most cases, without reference to health outcomes. We review these studies here as they relate to Key Question #2.

### Use of Medication

(Appendix C, Table 9)

There were a number of studies that examined the use of prescription medications without associating medication use with health outcomes. The studies on medication use examined prevalence and/or intensity of medication use,56,89-94 expenditures for prescription drugs,92,93,95 likelihood of having a usual pharmacy,94 and degree of change in postdischarge medication regimen.56 All of the study samples consisted of outpatients over 65 years old. Three studies92,93,95 used national samples and the rest used samples from a single state. Two of the studies92,95 that had used a national sample had relatively small sample sizes (N<1,100). The sample sizes for the single-state studies varied widely, ranging from 32^56^ to 18,641.^91^ One study was of moderate quality, three were of low to moderate quality, and four were of low quality.

Of the seven studies that examined prevalence and/or intensity of medication use, all but one were rated with moderate to low Confidence Scores. Among these studies, five reported significant rural-urban differences on the number of medications used; however, the direction of effects was inconsistent. Comparing the number of medications prescribed for cardiac patients discharged from a tertiary hospital, Dellasega et al. (1999) found a greater number of drugs prescribed over time for urban patients than for rural patients (e.g., 5.9 vs. 4.2 for urban and rural, respectively, at four weeks post-discharge), even after controlling for severity of illness at time of discharge.56 Similarly, Hanlon et al. (1996) found greater use of prescription drugs among urban elderly residents than their rural counterparts (OR=1.40, 95% 95%CI 1.18-2.04).90 Mueller and Schur (2004), on the other hand, found greater number of prescriptions filled by elderly rural Medicare beneficiaries compared to elderly urban beneficiaries (for those with drug coverage, medians of 23 and 20.8, p<0.01, for rural and urban, respectively; for those without drug coverage, medians of 18.1 and 16.0, p<0.05, for rural and urban, respectively).93 Notably, rural residents were somewhat less likely to have coverage for prescription drugs (59.4% rural vs. 75.4% urban, p<0.01).

In a study of non-cognitively impaired residents 65 years and older in western Texas, Xu et al. (2003) found no difference in the odds of prescription drug use between individuals living in urban counties and those living in rural counties (i.e., counties outside of MSA or with a population less than 50,000); however, those living in frontier counties (i.e., counties with fewer than 7 people per square mile) had lower odds (OR=0.59, p<0.01) of prescription medication receipt.94

In contrast to these findings from lower quality studies, a large study of 18,641 Pennsylvania residents by Lago et al, (1993) did not find a rural-urban difference in medical claims for the number of prescriptions.91 Other studies using national samples similarly found no rural-urban difference in drug expenditures between rural and urban residents.92.^93^ Some support was found for a race by population density interaction for medication use in a study of 4,163 residents in North Carolina.89 Specifically, urban whites were more likely to take greater number of prescription drugs than rural whites (β=0.21, SE=0.10, p<0.05), but there was no association between rurality and intensity of prescription drug use among blacks (β=0.12, SE=0.08, ns). A secondary analysis of data from a national survey of 996 elderly participants also failed to find rural-urban differences in the percentage of family income spent on drugs after controlling for income, insurance, and health status.95

The odds of having a usual pharmacy were lower for frontier county residents compared to urban residents in West Texas (OR=0.64, p<0.01), but rural residents were more likely to report that their pharmacies provided medication delivery services.94

### Medical Procedures and Diagnostic Tests

(Appendix C, Table 10)

Two studies, both of which received low Confidence Scores, looked at use of medical procedures or diagnostic tests. Miller (1995) examined use of medical procedures and services provided by physicians among rural and urban Medicare beneficiaries.96 The use of most services, including office visits and consultations, imaging services, and diagnostic testing, were found to be lower in rural areas compared to urban areas. Focusing on racial disparities in service utilization, Escarce et al. (1993) compared use of 32 medical procedures between white and black patients living in urban and rural areas.97 The results showed an interaction of rurality and race on 8 (or 57%) of 14 outpatient medical procedures, with racial disparities being greater in rural than in urban areas.

### Medical Appointments with Providers

(Appendix C, Table 11)

Findings were mixed across 10 studies (1 of high quality, 5 of moderate quality, 2 of low to moderate quality, and 2 of low quality) examining frequency of ambulatory care visits. While four studies found no differences in visit frequency between rural and urban,29,98-100 four studies found that number of appointments tended to increase as population density increased.8,101-103 Based on data from the 1984 National Health Interview Survey on people 65 yr and older, it was found that those who lived in non-metropolitan areas were 35% less likely than non-inner city metropolitan residents to visit a physician. Using a more recent cohort of that database (1992) and focusing on the 112,246 residents under 65 yr, Mueller and colleagues (1998) found that rural residents as a group were less likely to have seen a physician in the previous 12 months.103 Minority status and living in the Southern part of the US were independent predictors of not seeing a physician in the previous 12 months; however, the strongest predictor was a lack of insurance (OR=0.42, 95%CI=0.40-0.44). In a national study of any health care use in the past 12 months among 50,993 respondents to the National Health Interview Surveys from 1999-2000, 78% of urban residents and 79% of rural residents reported using at least some health care.100 Similar findings were reported by a second national study using the Medical Expenditures Panel Survey from 1996 which found no difference across rural or urban areas in the odds of having at least one ambulatory visit in the past year.102 However, rural residents reported fewer visits on average than residents of large metropolitan (4.9 visits vs. 6.1 visits, p<0.02). For individuals with at least one visit, the number of visits ranged from 6.5 for rural residents to 8.3 for large metropolitan residents (p<0.001).

Weeks et al. (2005) examined the number of primary, specialty, and mental health visits from 1997-1999 among rural vs. urban veterans 65 years and older living in New England.8 Rural veterans had fewer visits in all three treatment sectors. A study comparing 25,092 veterans at 108 community-based outpatient clinics (CBOCs) with 26,936 veterans at 72 VA medical centers (VAMCs) found more primary care visits (difference=0.10 visits) but fewer specialty care visits (difference=-1.42) per year among CBOC patients compared to VAMC patients.104 The same pattern of results was found an earlier study that used smaller samples of CBOCs and VAMCs.105

### Usual Source of Care

(Appendix C, Table 12)

We identified seven cross-sectional studies (two of moderate quality, three of low to moderate quality, and two of low quality) that addressed issues related to having a usual source of care (i.e., a specific clinic from which they receive care). Four of the studies included nationwide samples of patients with sample sizes ranging from 3,871 to 50,993.^48,100,102,106^ Three of the studies were regional, specifically west Texas107,108 and North Carolina.98 Sample sizes in these studies ranged from 2,097 to 4,162. One of the studies included only active duty, uniformed service members.106 Three studies included only patients age 65 and older,98,107,108 and one study included only patients 18 to 64 years of age.100 There was one study that compared only individuals of Hispanic or non-Hispanic white race/ ethnicity.107 Overall, we found that similar percentages of rural and urban residents report having a usual source of care. The percentages of rural and urban residents who reported having had a health care visit in the past year similarly did not differ by geographic location.

Six studies specifically looked at whether individuals had a usual source of care. In a large nationwide survey of individuals ages 18-64 years, 82% of urban respondents and 83% of rural respondents reported having a usual source of care.100 Although there was no difference in the odds of having a usual source of care between respondents from urban and rural areas, race/ ethnicity differences were found (e.g., 68% of Hispanics vs. 85% of whites reported a usual source of care) and these disparities were comparable in urban and rural areas.100 Koopman (2006), using the National Health and Nutrition Examination Survey from 1988-1994, also found that Urban Hispanics were more likely than either urban or rural whites or rural Hispanics to report a lack of usual source of health care (11.4% vs. 1.8% urban whites, 6.5% rural whites, and 5.1% rural Hispanics; p<0.01).48

In another national study with a similar patient population, the percentages of patients who reported having a usual source of care were 87% in the most rural counties, 89% in counties adjacent to a large metropolitan areas, 78% in large metropolitan counties, and 78% in smaller metropolitan counties.102 In the adjusted model, patients in the most rural areas and those in rural areas adjacent to large metropolitan areas were more likely to have a usual source of care than residents in large metropolitan areas. Other factors significantly associated with having a usual source of care included worse health and higher income.

Two regional studies of patients over 64 years old found that between 94% and 96% reported having a usual source of care with no difference between urban and rural residents98,108 In the adjusted model, having insurance other than Medicare/Medicaid was associated with increased odds of having a usual source of care while Hispanic ethnicity was associated with decreased odds.108 Both studies also looked at whether the respondent had a personal provider. No differences were found between rural and urban areas in the odds of having a personal provider (87%).108 Hispanic ethnicity and lower income were associated with decreased odds.108 The second study reported a rural advantage for continuity of care with a primary care provider (88% rural vs. 82% urban; p<0.05).98 A third study, comparing Hispanic and non-Hispanic whites in rural or frontier counties of west Texas reported that the likelihood of having a personal provider was not associated with degree of rurality; however, non-Hispanic whites were significantly more likely to report that they consulted their personal doctor or nurse.107

Three studies reported results related to ability to obtain care.98,106,107 A nationwide survey of over 3,800 Department of Defense beneficiaries found that health plans and health care, ability to get care quickly, and doctor communication were rated significantly higher by residents in areas adjacent to metropolitan areas or in non-adjacent areas. Getting needed care and customer services were rated higher by residents of metropolitan areas.106 A study of Hispanic and non-Hispanic whites in rural and frontier areas of west Texas found lower percentages of Hispanics reporting that they see a specialist when needed, that they are able to obtain transportation to the doctors' office, and that they see a doctor or nurse as soon as they want for both illness/injury and routine care. In an adjusted analysis, Hispanic ethnicity was no longer associated with decreased ability to obtain care but remained significantly associated with decreased ability to see a doctor or nurse when they wanted to. Residence in a frontier or rural county was not related to ability to obtain care or to obtain care without a long wait.98 Finally, in a study of 4,162 residents of urban or rural counties in North Carolina, 6% of the urban respondents and 10% of the rural respondents (a non-significant difference) reported that they put off care due to transportation difficulties while14% of urban and 25% of rural respondents put off care due to the cost (p<0.05).98

### Provider Availability and Expertise

(Appendix C, Table 13)

We identified 12 cross-sectional studies related to provider availability and expertise. Four studies were national studies.28,66,109,110 One study was conducted in eight states in southeastern United States.111 One study included clinicians from California and Washington.112 The remaining studies were conducted in Wisconsin,113 Texas,114 Florida,115,116 Washington,117 or Georgia.118 Three studies enrolled patients,110,111,113 seven studies enrolled providers,28,109,112,115-118 and two studies presented data by county.66,114 Two of the studies were of high quality, five were of low to moderate quality, and five were of low quality. Overall, the evidence suggests that more remote locations are underserved by health care providers. People who live in these areas are more likely to see a family practice physician, a physician assistant, or a nurse practitioner. In one state, services are being decreased or eliminated by both rural and urban physicians. There is limited nationwide data on this topic.

Nationwide, the availability of primary care physicians per 10,000 residents decreases in an almost linear fashion from an urban high of 17.8 (SD=16.1) to a low of 7.2 (SD=7.8) in rural areas adjacent to a micropolitan area.28 The ratio was slightly higher in remote rural regions with a ratio of 9.2 (SD=8.9),28 but the variability across remote regions can be highly problematic. For example, the distribution of physicians and physician assistants was examined in rural and remote counties of Texas using the Texas Medical Board Web site and from US Census Data.114 Seventeen of 254 Texas counties had no licensed doctors or physician assistants. Statewide, there was one physician assistant for every 13.6 physicians. In the 60 frontier counties, however, the ratio was one physician assistant for every 2.3 physicians. Frontier counties, then, have not only a diminished availability of medical providers, but more of the providers that they do have are physician extenders. Patient perceptions of physician availability were consistent with the epidemiologic assessments. Biola et al. (2009) surveyed 4,879 patients living in 150 rural counties in the southeastern United States, and examined agreement with the statement “I feel there are enough doctors in my community.”111 As would be expected, patients who lived in areas with more physicians relative to the county population were more likely to respond that there were enough physicians. Of interest, the perception that there were an insufficient number of physicians was greater not only among patients who live in areas with fewer physicians relative to county residents, but also among those who traveled more than 30 minutes for care, those who lived in a more impoverished county or who had problems with the cost of care, and among those who lacked confidence in their physician's level of expertise.

As noted previously, differences in provider availability were not only found for primary health care providers. A nationwide study of numbers of rehabilitation therapists (physical therapists, occupational therapists, and speech-language pathologists) between 1980-2000, found that although the disparity in therapist availability between rural and urban areas had improved over the 20 year period, that the ratio of therapists per 100,000 residents remained significantly different between urban and rural areas (urban:rural rates per 100,000 for physical therapists 50.9:35.5, occupational therapists 24.7:15.3, and speech pathologists 35.0:29.5).66

In addition to limitations in provider availability, rural residents often have different types of providers available to them. A nationwide study of over 34,000 patients from non-metropolitan areas had greater adjusted odds of receiving services from family physicians, nurse practitioners, or physician assistants and lower adjusted odds of receiving services from general internists or non-surgical specialists.110 Similarly, in the Wisconsin Longitudinal Study,113 primary provider type was determined among survey respondents who indicated they had a usual source of care and compared across metropolitan, micropolitan, or nonmetropolitan (i.e., rural) areas.113 Overall, 4.5% of respondents reported that a physician assistant or nurse practitioner was their primary care provider and, in adjusted analyses, these provider types were more common among nonmetropolitan residents. Also consistent with findings was a study of over 28,000 clinicians practicing in California and over 5,600 clinicians practicing in Washington State.112 Of physician assistants practicing in California, 22% were in rural areas. A similar pattern was observed in Washington. Family physicians, nurse practitioners, and physician assistants were more likely to practice in a rural area (relative to obstetrics/gynecology). Physician extenders in rural areas often work longer hours, see more patients and provide care to more patients without insurance than their urban counterparts.118 Differences were found not only in the prevalence of physician extenders, but also in the type of physicians practicing in rural areas. For example, in a study of over 4,000 providers in Washington State,117 family physicians were most likely to provide care in a rural area; psychiatrists, cardiologist, and gastroenterologists were least likely. Although the diagnostic scope of practice was similar for rural and urban physicians, rural obstetrician-gynecologists were more likely to care for diagnoses outside of their specialty and rural general surgeons were more likely to care for gastrointestinal disorders (vs. cardiac conditions for urban surgeons). Not surprisingly, procedure rates were higher for rural physicians.

Of concern is the fact that often the qualifications of physician extenders in rural areas may not be comparable to those practicing in urban settings. A survey of nurse practitioners, certified nurse midwives, and physician assistants in Georgia found that of 554 nurse practitioners who responded, 31% were working in a rural environment.118 Rural nurse practitioners were less likely to have had a bachelor's degree and fewer had specialty credentials. This may be particularly concerning given that they were more likely to provide care in solo and clinic practice settings. Of 73 certified nurse midwives, 29% worked in a rural setting. Rural certified nurse midwives also had fewer specialty credentials, worked more hours per week, and saw more patients per hour. Of the 18% of 452 physician assistants practicing in rural settings, fewer had at least a bachelor's degree compared to those practicing in urban settings. Although there is limited data comparing the quality of care between rural primary care providers who are physician extenders and those who are physicians, patients in the Wisconsin Longitudinal Study whose usual source of care was a physician assistant or nurse practitioner were more likely to report lower satisfaction with access to care (beta=−0.22, 95%CI=−0.35-−0.09), and were less likely to have received a complete health exam (OR=0.74, 95%CI = 0.55-0.99) or a mammogram (OR=0.65, 95%CI=0.45-0.93).113. However, a national Web survey of physician assistants in 2008 (response rate 49%), found that rural physician assistants were better at diagnosing and treating dermatologic conditions than their urban counterparts (p<0.03).109 This was interpreted as being most likely due to the larger number of dermatologic cases seen by rural practitioners (78% rural see most dermatologic cases vs. 62% of urban physician assistants). Importantly, the referral rate for specialty treatment did not differ by rural-urban practice settings.

Two studies, both conducted in Florida, reported that physicians in both urban and rural area were curtailing the services that they offered, largely in response to malpractice costs.115,116 Overall, 60% of 308 respondents from both rural and urban areas reported that “delivery of patient services in their practice had been decreased or eliminated in the last year.”116 Of the 539 respondents to a survey of rural physicians, 55% reported they decreased or eliminated patient services in the past year. Among the services decreased were mental health services (reported decreased by 35%), vaccine administration (29%), office-based surgeries (40%), Pap smears (24%), x-rays (24%), endoscopies (43%), and electrocardiograms (11%). Additionally, there was a significantly greater reduction or elimination of services, overall, by physicians who saw higher numbers of Medicare patients.115

### Summary

There is limited availability of any health care providers in highly rural areas, and specialists in particular. There was some weak evidence that physician extenders in rural areas may not have comparable credentials to their urban counterparts. Rural residents were more likely to have family medicine physicians as their primary care doctors, as well as primary providers who were physician extenders. Having fewer health care choices seemed to increase the odds of remaining with the same provider over time, thereby improving continuity of care. There is weak evidence that in some parts of the country, health care providers in highly rural areas may not have comparable credentials as their counterparts in urban area. It is unclear to what extent this might generalize to other areas.

Table 10 Confidence Scores for Processes or Structure of Care Studies

Study | Dellasaga 1999^56^ | Fillenbaum 1993^89^ | Hanlon 1996^90^ | Lago 1993^91^ | Lillard 1999^92^ | Mueller 2004^93^ | Xu 2003^94^ | Rogowski 1997^95^ | Miller 1995^96^ | Escarce 1993^97^ | Blazer 1995^98^ | McConell 1993^99^ | Saag 1998^29^ | Himes 1993^101^ | Larson 2003^102^ | Mueller 1998^103^ | Weeks 2005^8^ | Maciejewski 2007^104^ | Fortney 2002^105^ | Meza 2006^106^ | Glover 2004^100^ | Borders 2004^107^ | Rohrer 2004^108^ | Koopman 2006^48^ | Wilson 2009^66^ | Ferrer 2007^110^ | Biola 2009^111^ | Grumbach 2003^112^ | Everett 2009^113^ | Jones 2008^114^ | Gunderson 2006^115^ | Manachemi 2006^116^ | Baldwin 1999^117^ | Strickland 1998^118^ | Laditka 2009^28^ | Brown 2009^109^
Internal Validity (G, F, P) | F | G | G | F | F | F | F | F | F | F | F | F | F | F | F | F | F | G | F | P | G | F | F | F | G | F | F | F | F | G | F | F | G | F | G | P
Sampling Method/Bias | F | G | G | F | F | G | F | F | F | F | F | F | F | G | G | G | G | G | G | P | G | F | F | G | G | F | P | F | F | G | F | F | G | F | G | P
Predictors/Confounders | F | G | G | F | F | F | G | F | F | F | G | F | G | F | G | G | F | G | F | F | G | G | G | G | N/A | F | G | F | F | N/A | N/A | N/A | N/A | N/A | N/A | F
Outcomes | F | G | F | G | F | G | F | F | F | F | F | F | F | F | F | G | G | G | G | F | G | F | F | G | G | G | P | F | G | G | F | F | G | G | G | P
Statistical Methods | F | G | G | G | F | F | G | F | F | F | G | F | G | F | F | F | F | G | F | F | G | G | G | F | G | F | G | G | G | N/A | G | G | G | G | G | F
External Validity (G, F, P) | P | F | F | F | F | F | P | F | F | P | F | F | F | G | G | F | F | G | F | F | F | F | F | F | G/F | F | P | F | F | G | F | F | F | F | G | P
Use of proxy variables or aggregate measures | F | G | G | G | F | G | F | F | F | F | G | G | G | G | G | F | G | G | G | G | G | G | G | G | F | G | F | G | G | G | G | G | G | G | G | F
Representativeness of sample (size, composition) | P | F | F | F | F | G | F | F | F | F | F | F | F | G | G | G | G | G | G | P | G | F | P | F | G | F | F | F | F | G | F | F | F | F | G | F
Is the study design appropriate for the research question? | P | G | G | G | F | P | P | F | F | P | F | F | P | G | G | F | F | G | F | F | F | F | P | G | G | F | P | P | F | G | F | F | F | F | G | P
Overall Confidence Score | L | M/L | M/L | M | L | M/L | L | L | L | L | M/L | L | L | M | M | M | M | H | M | L | M | M/L | L | M | H/M | M/L | L | L | M/L | H | L | L | M/L | M/L | H | L