# REFERENCES

1 Veterans Health Administration, Department of Veterans Affairs, Office of Rural Health. About Rural Veterans. Available at: http://vaww.ruralhealth.va.gov/RURALHEALTH/About_Rural_Veterans.asp. April 29, 2011.
2 United States Department of Agriculture. Rural Population and Migration. 2009. Available at: http://www.ers.usda.gov/Briefing/Population/. April 29, 2011.
3 Veterans Health Administration, Department of Veterans Affairs, Office of Rural Health. Demographic Characteristics of Rural Veterans. Available at: http://vaww.ruralhealthva.gov/RURALHEALTH/docs/IBDemographicCharacteristics.pdf. April 29, 2011.
4 Weeks WB, Kazis LE, Shen Y. Differences in health-related quality of life in rural and urban veterans. Am J Public Health. 2004;94(10):1762-7. [pmid: 15451747].
5 Weeks WB, Wallace AE, Wang S, Lee A, Kazis LE. Rural-urban disparities in health-related quality of life within disease categories of Veterans. J Rural Health. 2006;22(3):204-11. [pmid: 16824163].
6 Wallace AE, MacKenzie TA, Wright SM, Weeks WB. A cross-sectional, multi-year examination of rural and urban Veterans Administration users: 2002-2006. Mil Med. 2010;175(4):252-8. [pmid: 20446500].
7 Wallace AE, Lee R, MacKenzie TA, et al. A longitudinal analysis of rural and urban veterans' health-related quality of life. J Rural Health. 2010;26(2):156-63. [pmid: 20447002].
8 Weeks WB, Bott DM, Lamkin PR, Wright SM. Veterans Health Administration and Medicare outpatient health care utilization by older rural and urban New England veterans. J Rural Health. 2005;21(2):167-71. [pmid: 15859054].
9 West AN, Weeks WB. Health care expenditures for urban and rural veterans in veterans health administration care. Health Serv Res. 2009;44(5 Pt 1):1718-34. [pmid: 19500162].
10 Institute of Medicine. Unequal treatment: confronting racial and ethnic disparities in health care. Washington DC. The National Academies Press. 2003.
11 Weeks WB, Wallace AE, West AN, Heady HR, Hawthorne K. Research on rural veterans: An analysis of the literature. J Rural Health. 2008;24(4):337-44. [pmid: 19007387].
12 Stern S, Merwin E, Hauenstein E, et al. The effects of rurality on mental and physical health. Health Serv Outcomes Res Methods. 2010;10:33-66.
13 West AN, Lee RE, Shambaugh-Miller ME, et al. Defining “rural” for veterans' health care planning. J Rural Health. 2010;26(4):301-9. [pmid: 21029164].
14 Berke EM, West AN, Wallace AE, Weeks WB. Practical and policy implications of using different rural-urban classification systems: a case study of inpatient service utilization among Veterans Administration users. J Rural Health. 2009;25(3):259-66. [pmid: 19566611].
15 Institute of Medicine. Redesigning the clinical effectiveness research paradigm: Innovation and practice-based approaches: Workshop summary. Olsen L, McGinnis JM, editors. Washington DC. The National Academies Press. 2010.
16 Owens DK, Lohr KN, Atkins D, et al. Grading the strength of a body of evidence when comparing medical interventions-Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. 2009;63:513-23.
17 Shamliyan TA, Kane RL, Ansari M, et al. Development quality criteria to evaluate non-therapeutic studies of incidence, prevalence, or risk factors of chronic diseases: pilot study of new checklists. J Clin Epidemiol. 2011;64:637-57. [pmid: 21071174].
18 Casey MM, Thiede Call K, Klinger JM. Are rural residents less likely to obtain recommended preventive healthcare services?. Am J Prev Med. 2001;21:182-8. [pmid: 11567838].
19 Zhang P, Tao G, Irwin KL. Utilization of preventive medical services in the United States: a comparison between rural and urban populations. J Rural Health. 2000;16(4):349-56. [pmid: 11218321].
20 Brown KC, Fitzhugh EC, Neutens JJ, Klein DA. Screening mammography utilization in Tennessee women: The association with residence. J Rural Health. 2009;25:167-73. [pmid: 19785582].
21 Coughlin SS, Leadbetter S, Richards T, Sabatino SA. Contextual analysis of breast and cervical cancer screening and factors associated with health care access among United States women, 2002. Soc Sci Med. 2008;66:260-75. [pmid: 18022299].
22 Coughlin SS, Thompson TD. Colorectal cancer screening practices among men and women in rural and nonrural areas of the United States, 1999. J Rural Health. 2004;20:118-24. [pmid: 15085624].
23 Coughlin SS, Thompson TD, Hall HI, Logan P, Uhler RJ. Breast and cervical carcinoma screening practices among women in rural and nonrural areas of the United States, 1998-1999. Cancer. 2002;94:2801-12. [pmid: 12115366].
24 Kinney AY, Harrell J, Slattery M, Martin C, Sandler RS. Rural-urban differences in colon cancer risk in blacks and whites: the North Carolina Colon Cancer Study. J Rural Health. 2006;22(2):124-30. [pmid: 16606423].
25 Schootman M, Fuortes LJ. Breast and cervical carcinoma: The correlation of activity limitations and rurality with screening, disease incidence, and mortality. Cancer. 1999;86(6):1087-94. [pmid: 10491538].
26 Stearns SC, Slifkin RT, Edin HM. Access to care for rural Medicare beneficiaries. J Rural Health. 2000;16(1):31-42. [pmid: 10916313].
27 Epstein B, Grant T, Schiff M, Kasehagen L. Does rural residence affect access to prenatal care in Oregon?. J Rural Health. 2009;25:150-157. [pmid: 19785580].
28 Laditka JN, Laditka SB, Probst JC. Health care access in rural areas: Evidence that hospitalization for ambulatory care-sensitive conditions in the United States may increase with the level of rurality. Health Place. 2009;15(3):761-70. [pmid: 19217818].
29 Saag KG, Doebbeling BN, Rohrer JE, et al. Variation in tertiary prevention and health service utilization among the elderly: The role of urban-rural residence and supplemental insurance. Med Care. 1998;36:965-76. [pmid: 9674615].
30 Schreiber S, Zielinski T. The meaning of ambulatory care sensitive admissions: urban and rural perspectives. J Rural Health. 1997;13(4):276-84. [pmid: 10177149].
31 Edwards JB, Tudiver F. Women's preventive screening in Rural Health Clinics. Women's Health Issues. 2008;18(3):155-66. [pmid: 18457753].
32 Probst JC, Laditka JN, Laditka SB. Association between community health center and rural health clinic presence and county-level hospitalization rates for ambulatory care sensitive conditions: an analysis across eight US states. BMC Health Serv Res. 2009;9:134. Epub 2009 31 July. [pmid: 19646234].
33 Shugarman LR, Sorbero ME, Tian H, Jain AK, Ashwood JS. An exploration of urban and rural differences in lung cancer survival among Medicare beneficiaries. Am J Public Health. 2008;98(7):1280-7. [pmid: 17971555].
34 Loberiza FR, Cannon AJ, Weisenburger DD, et al. Survival disparities in patients with lymphoma according to place of residence and treatment provider: A population based study. J Clin Oncol. 2009;27:5376-82. [pmid: 19752339].
35 Elliott TE, Elliott BA, Renier CM, Haller IV. Rural-urban differences in cancer care: results from the Lake Superior Rural Cancer Care Project. Minn Med. 2004;87(9):44-50.
36 Chirumbole M, Gusani N, Howard A, Leonard T, Lewis P, Muscat J. A comparison of stage of presentation for pancreatic and colorectal cancer in Pennsylvania 2000-2005. Anticancer Res. 2009;29:3427-32. [pmid: 19661368].
37 Higginbotham JC, Moulder J, Currier M. Rural v. urban aspects of cancer: first-year data from the Mississippi Central Cancer Registry. Fam Community Health. 2001;24(2):1-9.
38 Paquette I, Finlayson SRG. Rural versus urban colorectal and lung cancer patients: Differences in stage at presentation. J Am Coll Surg. 2007;205(5):636-41. [pmid: 17964438].
39 McLafferty S, Wang F. Rural reversal? Rural-urban disparities in late-stage cancer risk in Illinois. Cancer. 2009;115:2755-64. [pmid: 19434667].
40 Sankaranarayanan J, Watanabe-Galloway S, Sun J, Qiu F, Boilesen E, Thorson AG. Rurality and other determinants of early colorectal cancer diagnosis in Nebraska: A 6-year cancer registry study, 1998-2003. J Rural Health. 2009;25:358-65. [pmid: 19780915].
41 McLaughlin J, Balkrishnan R, Paskett ED, Kimmick GG, Anderson RT. Patient and provider determinants associated with the prescription of adjuvant hormonal therapies following a diagnosis of breast cancer in Medicaid-enrolled patients. J Natl Med Assoc. 2009;101:1112-8. [pmid: 19998639].
42 Schootman M, Aft R. Rural-urban differences in radiation therapy for ductal carcinoma in-situ of the breast. Breast Cancer Res Treat. 2001;68(2):117-25. [pmid: 11688515].
43 Baldwin LM, Cai Y, Larson EH, et al. Access to cancer services for rural colorectal cancer patients. J Rural Health. 2008;24(4):390-9. [pmid: 19007394].
44 O'Hare AM, Johansen KL, Rodriguez RA. Dialysis and kidney transplantation among patients living in rural areas of the United States. Kidney Int. 2006;69(2):343-9. [pmid: 16408125].
45 Krishna S, Gillespie KN, McBride TM. Diabetes burden and access to preventive care in the rural United States. J Rural Health. 2010;26(1):3-11. [pmid: 20105262].
46 Ward MM. Access to care and the incidence of end-stage renal disease due to diabetes. Diabetes Care. 2009;32(6):1032-6. [pmid: 19460914].
47 Andrus MR, Kelley KW, Murphey LM, Herndon KC. A comparison of diabetes care in rural and urban medical clinics in Alabama. J Community Health. 2004;29(1):29-44. [pmid: 14768933].
48 Koopman RJ, Mainous AG, Geesey ME. Rural residence and Hispanic ethnicity: Doubly disadvantaged for diabetes?. J Rural Health. 2006;25:63-8.
49 Morden NE, Berke EM, Welsh DE, McCarthy JF, MacKenzie TA, Kilbourne AM. Quality of care for cardiometabolic disease: Associations with mental disorder and rurality. Med Care. 2010;48:72-78. [pmid: 19927015].
50 Rosenblatt RA, Baldwin LM, Chan L, et al. Improving the quality of outpatient care for older patients with diabetes: lessons from a comparison of rural and urban communities. J Fam Pract. 2001;50(8):676-80. [pmid: 11509161].
51 Weingarten JP, Brittman S, Hu W, Przybyszewski C, Hammond JM, FitzGerald D. The state of diabetes care provided to Medicare beneficiaries living in rural America. J Rural Health. 2006;22(4):351-8. [pmid: 17010033].
52 Kirkbride K, Wallace N. Rural health clinics and diabetes-related primary care for Medicaid beneficiaries in Oregon. J Rural Health. 2009;25:247-52. [pmid: 19566609].
53 Hicks PC, Bublitz Emsermann C, Westfall JM, Parnes B. Comparison of HTN management in patients with diabetes between rural and urban primary care clinics in Northeastern Colorado – a report from SNOCAP. Rural Remote Health. 2010;10:1279. Epub 2010 Feb 12. [pmid: 20148599].
54 King DE, Crisp JR. Rural-urban differences in factors associated with poor blood pressure control among outpatients. South Med J. 2006;99(11):1221-3. [pmid: 17195416].
55 Colleran KM, Richards A, Shafer K. Disparities in cardiovascular disease risk and treatment: demographic comparison. J Investig Med. 2007;55(8):415-22.
56 Dellasega C, Orwig D, Ahern F, Lenz E. Postdischarge medication use of elderly cardiac patients from urban and rural locations. J Gerontol A Biol Sci Med Sci. 1999;54A:M514-20.
57 Whyte BM, Carr JC. Comparison of AIDS in women in rural and urban Georgia. South Med J. 1992;85(6):571-8. [pmid: 1604384].
58 Cohn SE, Berk ML, Berry SH, et al. The care of HIV-infected adults in rural areas of the United States. J Acquir Immune Defic Syndr. 2001;28(4):385-92. [pmid: 11707677].
59 Napravnik S, Eron JJ, McKaig RG, Hein AD, Menezes P, Quinlivan EB. Factors associated with fewer visits for HIV primary care at a tertiary care center in the Southeastern U.S. AIDS Care. 2006;18(Suppl 1):S45-50. [pmid: 16938674].
60 Schur CL, Berk ML, Dunbar JR, Shapiro MF, Cohn SE, Bozzette SA. Where to seek care: An examination of people in rural areas with HIV/AIDS. J Rural Health. 2002;18:337-47. [pmid: 12135154].
61 Buchanan RJ, Schiffer R, Stuifbergen A, et al. Demographic and disease characteristics of people with multiple sclerosis living in urban and rural areas. Int J MS Care. 2006;8(3):89-98.
62 Buchanan RJ, Wang S, Stuifbergen A, Chakravorty BJ, Zhu L, Kim M. Urban/rural differences in the use of physician services by people with multiple sclerosis. NeuroRehabilitation. 2006;21(3):177-87. [pmid: 17167187].
63 Buchanan RJ, Schiffer R, Wang S, et al. Satisfaction with mental health care among people with multiple sclerosis in urban and rural areas. Psychiatr Serv. 2006;57(8):1206-9. [pmid: 16870975].
64 Schootman M, Fuortes L. Functional status following traumatic brain injuries: population-based rural-urban differences. Brain Inj. 1999;13:995-1004. [pmid: 10628504].
65 Johnstone B, Nossaman LD, Schopp LH, Holmquist L, Rupright SJ. Distribution of services and supports for people with traumatic brain injury in rural and urban Missouri. J Rural Health. 2002;18:109-17. [pmid: 12043749].
66 Wilson RD, Lewis SA, Murray PK. Trends in the rehabilitation therapist workforce in underserved areas: 1980-2000. J Rural Health. 2009;25:26-32. [pmid: 19166558].
67 Gibbons RD, Hur K, Bhaumik DK, Mann JJ. The relationship between antidepressant medication use and rate of suicide. Arch Gen Psychiatry. 2005;62(2):165-72. [pmid: 15699293].
68 Fiske A, Gatz M, Hannell E. Rural suicide rates and availability of health care providers. J Community Psychol. 2005;33(5):537-43.
69 Rost K, Zhang M, Fortney J, Smith J, Smith GR. Rural-urban differences in depression treatment and suicidality. Med Care. 1998;36(7):1098-107. [pmid: 9674626].
70 Fortney J, Rushton G, Wood S, et al. Community-level risk factors for depression hospitalizations. Adm Policy Ment Health & Ment Health Serv Res. 2007;34:343-52.
71 Fortney JC, Xu S, Dong F. Community-level correlates of hospitalizations for persons with schizophrenia. Psychiatr Serv. 2009;60:772-8. [pmid: 19487346].
72 Farrell SP, Koch JR, Blank M. Rural and urban differences in continuity of care after state hospital discharge. Psychiatr Serv. 1996;47(6):652-4. [pmid: 8726498].
73 Fischer EP, McSweeney JC, Pyne JM, et al. Influence of family involvement and substance use on sustained utilization of services for schizophrenia. Psychiatr Serv. 2008;59(8):902-8. [pmid: 18678688].
74 Fortney J, Rost K, Zhang M, Warren J. The impact of geographic accessibility on the intensity and quality of depression treatment. Med Care. 1999;37:884-93. [pmid: 10493467].
75 Mohamed S, Neale M, Rosenheck RA. VA intensive mental health case management in urban and rural areas: veteran characteristics and service delivery. Psychiatr Serv. 2009;60(7):914-21. [pmid: 19564221].
76 Rost K, Owen RR, Smith J, Smith GR. Rural-urban differences in service use and course of illness in bipolar disorder. J Rural Health. 1998;14(1):36-43.
77 Rost K, Fortney J, Zhang M, Smith J, Smith GR. Treatment of depression in rural Arkansas: policy implications for improving care. J Rural Health. 1999;15(3):308-15. [pmid: 11942563].
78 Rost K, Adams S, Xu S, Dong F. Rural-urban differences in hospitalization rates of primary care patients with depression. Psychiatr Serv. 2007;58(4):503-8. [pmid: 17412852].
79 Elhai JD, Baugher SN, Quevillon RP, Sauvageot J, Frueh BC. Psychiatric symptoms and health service utilization in rural and urban combat veterans with posttraumatic stress disorder. J Nerv Ment Dis. 2004;192(10):701-4. [pmid: 15457114].
80 Booth BM, Kirchner J, Fortney J, Ross R, Rost K. Rural at-risk drinkers: correlates and one-year use of alcoholism treatment services. J Stud Alcohol. 2000;61(2):267-77. [pmid: 10757138].
81 Grant BF. Toward an alcohol treatment model: a comparison of treated and untreated respondents with DSM-IV alcohol use disorders in the general population. Alcohol Clin Exp Res. 1996;20(2):372-8. [pmid: 8730232].
82 Metsch LR, McCoy CB. Drug treatment experiences: rural and urban comparisons. Subst Use Misuse. 1999;34(4-5):763-84. [pmid: 10210104].
83 Robertson EB, Donnermeyer JF. Illegal drug use among rural adults: mental health consequences and treatment utilization. Am J Drug Alcohol Abuse. 1997;23(3):467-84. [pmid: 9261493].
84 Fortney JC, Booth BM, Blow FC, Bunn JY, Loveland Cook CA. The effects of travel barriers and age on the utilization of alcoholism treatment aftercare. Am J Drug Alcohol Abuse. 1995;21(3):391-406. [pmid: 7484987].
85 Petterson SM. Metropolitan-nonmetropolitan differences in amount and type of mental health treatment. Arch Psychiatr Nurs. 2003;17(1):12-9. [pmid: 12642883].
86 Petterson S, Williams IC, Hauenstein EJ, Rovnyak V, Merwin E. Race and ethnicity and rural mental health treatment. J Health Care Poor Underserved. 2009;20(3):662-77. [pmid: 19648696].
87 Hauenstein EJ, Petterson S, Merwin E, Rovnyak V, Heise B, Wagner D. Rurality, gender, and mental health treatment. Fam Community Health. 2006;29(3):169-85. [pmid: 16775467].
88 Wang PS, Lane M, Olfson M, Pincus HA, Wells KB, Kessler RC. Twelve-month use of mental health services in the United States: Results from the National Comorbidity Survey Replication. Arch Gen Psychiatry. 2005;62(6):629-40. [pmid: 15939840].
89 Fillenbaum GG, Hanlon JT, Corder EH, Ziqubu-Page T, Wall WE, Brock D. Prescription and nonprescription drug use among black and white community-residing elderly. Am J Public Health. 1993;83(11):1577-82. [pmid: 8238682].
90 Hanlon JT, Landerman LR, Wall WE, et al. Is medication use by community-dwelling elderly people influenced by cognitive function?. Age Aging. 1996;25(3):190-6.
91 Lago D, Stuart B, Ahern F. Rurality and prescription drug utilization among the elderly: an archival study. J Rural Health. 1993;9(1):6-16. [pmid: 10124200].
92 Lillard LA, Rogowski J, Kington R. Insurance coverage for prescription drugs: effects on use and expenditures in the Medicare population. Med Care. 1999;37(9):926-36. [pmid: 10493470].
93 Mueller C, Schur C. Insurance coverage of prescription drugs and the rural elderly. J Rural Health. 2004;20(1):17-25. [pmid: 14964924].
94 Xu KT, Smith SR, Borders TF. Access to prescription drugs among noninstitutionalized elderly people in west Texas. Am J Health-Syst Pharm. 2003;60:675-82. [pmid: 12701549].
95 Rogowski J, Lillard LA, Kington R. The financial burden of prescription drug use among elderly persons. Gerontologist. 1997;37(4):475-82. [pmid: 9279036].
96 Miller ME, Holahan J, Welch WP. Geographic variations in physician service utilization. Med Care Res Rev. 1995;52(2):252-78. [pmid: 10154562].
97 Escarce JJ, Epstein KR, Colby DC, Schwartz JS. Racial differences in the elderly's use of medical procedures and diagnostic tests. Am J Public Health. 1993;83(7):948-54. [pmid: 8328615].
98 Blazer DG, Landerman LR, Fillenbaum G, Horner R. Health services access and use among older adults in North Carolina: urban vs rural residents. Am J Public Health. 1995;85(10):1384-90. [pmid: 7573622].
99 McConnel CE, Zetzman MR. Urban/rural differences in health service utilization by elderly persons in the United States. J Rural Health. 1993;9(4):270-80. [pmid: 10131304].
100 Glover S, Moore CG, Probs JC, Samuels ME. Disparities in access to care among rural working-age adults. J Rural Health. 2004;20(3):193-205. [pmid: 15298093].
101 Himes CL, Rutrough TS. Differences in the use of health services by metropolitan and nonmetropolitan elderly. J Rural Health. 1994;10(2):80-8. [pmid: 10134716].
102 Larson SL, Fleishman JA. Rural-urban differences in usual source of care and ambulatory service use: analyses of national data using Urban Influence Codes. Med Care. 2003;41(7 Suppl):III-65-74. [pmid: 12865728].
103 Mueller KJ, Patil K, Boilesen E. The role of uninsurance and race in healthcare utilization by rural minorities. Health Serv Res. 1998;33(3 Pt 1):597-610. [pmid: 9685124].
104 Maciejewski ML, Perkins M, Li YF, Chapko M, Fortney JC, Liu CF. Utilization and expenditures of veterans obtaining primary care in community clinis and VA medical centers: an observational cohort study. BMC Health Serv Res. 2007;7:56. Epub 2007 18 April. [pmid: 17442115].
105 Fortney JC, Borowsky SJ, Hedeen AN, Maciejewski ML, Chapko MK. VA Community-Based Outpatient Clinics: Access and utilization performance measures. Med Care. 2002;40(7):561-9. [pmid: 12142771].
106 Meza JL, Chen LW, William TV, Ullrich F, Mueller KJ. Differences in beneficiary assessments of health care between TRICARE Prime and TRICARE Prime Remote. Mil Med. 2006;171(10):950-4. [pmid: 17076445].
107 Borders TF. Rural community-dwelling elders' reports of access to care: are there Hispanic versus non-Hispanic white disparities?. J Rural Health. 2004;20(3):210-20. [pmid: 15298095].
108 Rohrer JE, Kruse G, Zhang Y. Hispanic ethnicity, rural residence, and regular source of care. J Community Health. 2004;29(1):1-13. [pmid: 14768931].
109 Brown B, Bushardt R, Harmon K, Nguyen SA. Dermatology diagnoses among rural and urban physician assistants. JAAPA. 2009;22(12):32-5.
110 Ferrer RL. Pursuing equity: Contact with primary care and specialist clinicians by demographics, insurance, and health status. Ann Fam Med. 2007;5(6):492-502. [pmid: 18025486].
111 Biola H, Pathman DE. Are there enough doctors in my rural community? Perceptions of the local physician supply. J Rural Health. 2009;25(2):115-23. [pmid: 19785576].
112 Grumbach K, Hart LG, Mertz E, Coffman J, Palazzo L. Who is caring for the underserved? A comparison of primary care physicians and nonphysician clinicians in California and Washington. Ann Fam Med. 2003;1(2):97-104. [pmid: 15040439].
113 Everett CM, Schumacher JR, Wright A, Smith MA. Physician assistants and nurse practitioners as a usual source of care. J Rural Health. 2009;25(4):407-14. [pmid: 19780923].
114 Jones PE. Doctor and physician assistant distribution in rural and remote Texas counties. Aust J Rural Health. 2008;16(6):389. [pmid: 19032215].
115 Gunderson A, Menachemi N, Brummel-Smith K, Brooks R. Physicians who treat the elderly in rural Florida: trends indicating concerns regarding access to care. J Rural Health. 2006;2(3):224-8.
116 Menachemi N, Brooks RG, Clawson A, Stine C, Beitsch L. Continuing decline in service delivery for family physicians: is the malpractice crisis playing a role?. Qual Manag Health Care. 2006;15(1):39-45. [pmid: 16456479].
117 Baldwin LM, Rosenblatt RA, Schneeweiss R, Lishner DM, Hart LG. Rural and urban physicians: does the content of their Medicare practices differ?. J Rural Health. 1999;15(2):240-251. [pmid: 10511761].
118 Strickland WJ, Strickland DL, Garretson C. Rural and urban nonphysician providers in Georgia. J Rural Health. 1998;14(2):109-20. [pmid: 9714999].
119 United States Census Bureau. 2009 American Community Survey 1-Year Estimates, Geographic Comparison Tables. 2009. Available at: http://factfinder.census.gov/servlet/DatasetMainPageServlet?_program=ACS. April 29, 2011.
120 Brookhart MA, Stümer T, Glynn RJ, Rassen J, Schneeweiss S. Confounding control in healthcare database research: challenges and potential approaches. Med Care. 2010;48(6 Suppl):S114-20. [pmid: 20473199].
121 Walsh ME, Katz MA, Sechrest L. Unpacking cultural factors in adaptation to type 2 diabetes mellitus. Med Care. 2002;40(1 Suppl):I129-39. [pmid: 11789625].
122 United States Department of Health and Human Services, Agency for Healthcare Research and Quality. National Healthcare Disparities Report. 2010. Available at: http://www.ahrq.gov/qual/qrdr10.htm. April 29, 2011.
123 Veterans Health Administration, Department of Veterans Affairs. 2010 VHA Facility Quality and Safety Report. 2010. Available at: http://www.va.gov/health/docs/Hospital-ReportCard2010.pdf. April 29, 2011.
124 Cully JA, Lameson JP, Phillips LL, Kunik ME, Fortney JC. Use of psychotherapy by rural and urban veterans. J Rural Health. 2010;26:225-33. [pmid: 20633090].
125 Fortney JC, Harman JS, Xu S, Dong F. The association between rural residence and the use, type, and quality of depression care. J Rural Health. 2010;26:205-13. [pmid: 20633088].
126 O'Neill L. The effect of insurance status on travel time for rural Medicare patients. Med Care Res Rev. 2004;61(2):187-202. [pmid: 15155051].
127 Rost K, Fortney J, Fischer E, Smith J. Use, quality, and outcomes of care for mental health: the rural perspective. Med Care Res Rev. 2002;59(3):231-65. [pmid: 12205828].