# METHODS

## TOPIC DEVELOPMENT

This project was nominated by HSR&D and the Office of Rural Health. The analytic framework and key questions were developed with input from technical expert panel members Brian Bair, MD; John Fortney, PhD; Peter Kaboli, MD, MS; Ryan Lilly, MPA; and Alan West, PhD.

The analytic framework is depicted in Figure 1. The final key questions are:

- Key Question #1. Do adults with health care needs who live in rural areas have different intermediate (e.g., HbA1c, Blood pressure, etc.) or final health care outcomes (i.e., mortality, morbidity, QOL) than those living in urban areas?
- Key Question #2. Is the structure (e.g., types of available providers) or the process (e.g., likelihood of referral) of health care different for adults with health care needs who live in urban vs. rural environments?
- Key Question #3. If there are differences in the structure or the process of health care in rural vs. urban environments, do those differences contribute to variation in overall or intermediate health outcomes for adults with health care needs?
- Key Question #4. If there are differences in intermediate or final health outcomes for adult patients with health care needs, what systems factors other than those due to differences in health care structure or process moderate those differences (e.g., travel distance)?

Figure 1 Analytic Framework

## SEARCH STRATEGY

We searched OVID MEDLINE, PsycINFO, and CINAHL from 1990 to June, 2010 using the following MEDLINE search terms (or the corresponding terms in PsycINFO and CINAHL): hospitals, rural; rural health; rural population; rural health services, and United States. Limits to the search included English language, published 1990 or later, population age of 18 years or older, and publication types randomized controlled trial, clinical trial, cohort or cross-sectional study, meta-analysis, or review. Additionally, we did a hand search of references lists of relevant articles and of The Journal of Rural Health using the limits noted above.

## STUDY SELECTION

The principal investigator, co-investigators, and one of the research associates, all with experience in critical review of published studies, reviewed abstracts of articles identified in the search and selected articles for further review based on pre-defined exclusion criteria. In addition to the exclusion criteria used to limit the search, we also excluded articles if they were not about health care (e.g., focused on disease prevalence), if they did not include patients from rural settings, or if they were not about ambulatory care. Eligible articles provided primary data relevant to the key questions.

## DATA ABSTRACTION

Data from eligible articles was abstracted by the principal investigator, co-investigators, and one of the research associates onto a brief screening form (see Appendix A). The principal investigator developed the form and all abstractors completed forms for a common set of six articles. Results of the trial abstraction were reviewed with the principal investigator. The abstraction form captured data on the study design, sample (including whether the subjects in the study were Veterans), definition of rural used in the study, data source including the date of datesets used, analyses including covariates, and outcome measures.

## DATA SYNTHESIS

Because we wished to examine the body of evidence related to specific areas of health care, the studies were reviewed with other studies in that area. We constructed evidence tables showing the study characteristics and results for all included studies. We critically analyzed studies to compare their characteristics, methods, and findings. We compiled a summary of findings for each clinical topic, and drew conclusions based on a qualitative synthesis of the findings.

## RATING THE BODY OF EVIDENCE

Due to the qualitative nature of the synthesis, standard methods for rating the body of evidence do not apply and there are no validated rating systems to compare the quality of observational studies. Based on the work of others,15,16,17 we developed a rating system that we used as a heuristic in our efforts to compare studies that used different methodologies and to facilitate a synthesis of the evidence base in each content area. Although these ratings are essentially qualitative in nature, they provide the reader with information regarding our evaluations of the studies and, consequently, the overall evidence base. For each study, we evaluated the internal and the external validity, and then assigned an overall Confidence Score based on these ratings. The principal investigator and one of the co-investigators rated all articles after independently rating a set of 20 articles and reviewing the results. In Table 2 we detail the scales used and the kinds of elements that were considered within each rating category.

Table 2 Explanation of Confidence Scores

Internal Validity | Rated G(Good), F(Fair), P(Poor). In order to receive a “G” for internal validity would need to have “G” ratings for all subsumed elements.
Sampling Method/Bias | Low response rates without correction; convenience sampling;
Predictors/Confounders | Omission of socioeconomic/insurance factors or other factors usually associated with service use (e.g., age).
Outcomes | Unreliable or not validated measures; use of proxy variables (e.g., self-reported service use)
Statistical Methods | Omission of bivariate or multivariate statistics; Ignored data clustering
External Validity | Rated G(Good), F(Fair), P(Poor). In order to receive a “G” for external validity would need to have “G” ratings for all subsumed elements.
Use of proxy variables or aggregate measures | Use of county level predictors or outcomes in lieu of individual ones; Dichotomized urban rural without further gradations if urban/rural were a covariate in their model.
Representativeness of sample | Small samples; samples limited to one demographic group; no correction for biased sampling;
Study design appropriate for the research question? | Dichotomized urban rural without further gradations if area of residence was the focus of the study; poorly conceptualized study; data insufficient to answer primary research question.
Overall Confidence Score | Rated as follows:; - High Quality = further research unlikely to change confidence in effects. Both internal and external rated as “G”; - Moderate Quality= further research likely to have an important impact on confidence and may change the estimate of effect.; - Low Quality= further research is very likely to have an important impact and will likely change the estimate of effect.; - Very Low Quality= any estimate of effect is uncertain.; Note: “H” Overall Confidence Score would require “Good” ratings for both Internal and External Validity.

## PEER REVIEW

A draft version of this report was sent to nine peer reviewers. Their comments and our responses are presented in Appendix B.