# INTRODUCTION

## BACKGROUND

There are approximately 3 million veterans enrolled in the VA health care system who live in rural areas (as defined by VA) -- nearly 40% of the almost 8 million veterans who are current users of VA health care.1 Given that only 17% of the US population lives in rural areas, rural residents are disproportionately represented among veterans using VA services.2 This trend is likely to continue, as more than one-third of OEF/OIF veterans are from rural areas.3 The Rural Veterans Care Act of 2006 was signed into law to improve care for rural veterans. Ensuring that the health care needs of rural veterans are met has become a top priority for VA, resulting in a considerable expansion of community based outpatient clinics (CBOC's), inclusion of rural health/access as a research priority, and creation of the VA Office of Rural Health (ORH) in 2006.

A comparison of rural and urban veterans enrolled in VA health care in 1999 observed that rural veterans had lower overall health quality of life (both physical and mental), more comorbidities, and lower health quality of life within disease category than urban veterans.4,5 Although more recent assessments have shown that rural veterans appear to have comparable or even better mental health quality of life than urban veterans, the lower physical health quality of life in rural veterans has persisted over time.6,7 While differences in health care use between rural and urban veterans have been documented,8 it is unclear to what extent such differences in service use contribute to the observed differences in health outcomes. Some of the rural-urban difference in physical health quality of life among VA users is likely due to differences in disease prevalence,4 with elevated prevalence rates across numerous conditions among those rural veterans who use VA care.9 It remains to be determined, however, whether the observed lower health quality of life among rural veterans is due to differences in disease prevalence, disparities in health care or differences in other population characteristics. Because this review focuses on health care, differences in rural-urban prevalence rates of diseases and other health conditions are beyond its scope. This systematic review examines the evidence regarding potential disparities between rural and urban areas in health care provision and delivery, and how differences in health care may contribute to disparities in health outcomes.

Our first goal was to determine if a health care disparity exists across the urban-rural spectrum. For a disparity to exist, it would have to be demonstrated that health care outcomes of patients in rural areas differ from those of patients treated in urban areas for similar conditions. Because differences in health care process or delivery do not necessarily lead to disparities, we looked for evidence associating differences with poorer health outcomes. In their report, Unequal treatment: Confronting racial and ethnic disparities in healthcare, the Institute of Medicine10 defined disparity as, "…racial or ethnic differences in the quality of health care that are not due to access-related factors or clinical needs, preferences, and appropriateness of intervention"(pg 32). They go on to note, however, that inequity in care is often due to access-related factors, and that access differences are integrally tied to bias, stereotyping and inherent differences in health care systems. For the purposes of this review we conceptualized rural-urban disparities as differences in health care quality or availability.

A second goal of the review was to identify areas for intervention should any disparities be found. In order to develop a meaningful intervention, specific information regarding differences in the structure of health care and the way it is administered (i.e., the process) would be critical. Since differences in health outcomes can occur for reasons other than differences in the health care systems themselves (e.g., accessibility), our third goal was to examine what, if any, non-health care factors (e.g., travel distance to a clinic) affected health outcomes. Because veterans who use VA health care actually use more non-VA health care overall,9 we expanded the focus of this review to include comparisons of rural vs. urban health care in non-VA health systems.

## DEFINITIONS OF RURALITY

As noted in a review of the VA rural health literature by Weeks et al. (2008),11 synthesizing the literature on rural health is complicated by the methodologic and conceptual issues inherent in such a diverse literature. One recurrent problem is the lack of consistency across studies regarding the conventions used to define levels of rurality across communities, zip codes or counties.11 This inconsistency affects interpretation of the individual studies as well as comparability of findings across studies.12,13 It is beyond the scope of this review to address the complexities and ramifications of using specific population density classification schemes (for a discussion see Berke et al., 2009^14^; Stern et al., 2010^12^; West, 2010^13^). However, given the implications of this variation, we note the particular convention used to categorize rurality used in each study in the evidence tables for each section. For the convenience of readers who may be unfamiliar with these conventions, we provide a table of the most commonly used conventions along with a brief description of each (Table 1).

Table 1 Definitions of Urban and Rural (West et al. 2010;13 Berke et al. 2009^14^)

Rural/Urban Definitions | Unit of Rural Definition | Designations | Descriptions
Office of Management and Budget (OMB) Metropolitan and Micropolitan Areas (2000) | [underlined: County Level] | | The Office of Management and Budget (OMB) Metropolitan and Micropolitan statistical areas are a county level classifications defined by the existence of an urban core, the population of the urban core, and the economic and social integration of its surrounding territory measured by commuting ties. The OMB strongly cautions against the use of Metropolitan and Micropolitan Statistical Area Standards for defining urban-rural definitions due to the fact that all counties included in Metropolitan and Micropolitan Statistical Areas and many other counties contain both urban and rural territory and populations.
Office of Management and Budget (OMB) Metropolitan and Micropolitan Areas (2000) | [underlined: County Level] | Metropolitan Statistical Area | - Contains an Urbanized Area of 50,000 or more population and adjacent territory that has a high degree of social and economic integration with the core as measured by commuting ties
Office of Management and Budget (OMB) Metropolitan and Micropolitan Areas (2000) | [underlined: County Level] | Micropolitan Statistical Area | - Contains an Urban Core of at least 10,000, but less than 50,000, population and adjacent territory that has a high degree of social and economic integration with the core as measured by commuting ties
Office of Management and Budget (OMB) Metropolitan and Micropolitan Areas (2000) | [underlined: County Level] | Non-core based | - Based on an Urban Center of less than 10,000 people.
U.S. Department of Agriculture (USDA) Rural Urban Continuum Codes | [underlined: County Level] | | The 2003 USDA Rural-Urban Continuum Codes form a classification scheme that distinguishes metropolitan counties by size and nonmetropolitan counties by degree of urbanization and proximity to metro areas. This standard divides those of the Office of Management and Budget (OMB) into three metro and six non-metro categories, resulting in a 9-part county coding system. The standards for defining metropolitan areas were modified in 1958, 1971, 1975, 1980, 1990, and 2000. The current scheme was originally developed in 1974. This version allows researchers to specific populations based on population density and metro influence. Due to changes by the OMB's metro area delineation procedures for the 2000 Census, the current 2003 standards are not fully compatible with those of earlier years.
U.S. Department of Agriculture (USDA) Rural Urban Continuum Codes | [underlined: County Level] | Metro | - Counties in metro areas of 1 million population or more
U.S. Department of Agriculture (USDA) Rural Urban Continuum Codes | [underlined: County Level] | | - Counties in metro areas of 250,000 to 1 million population
U.S. Department of Agriculture (USDA) Rural Urban Continuum Codes | [underlined: County Level] | | - Counties in metro areas of fewer than 250,000 population
U.S. Department of Agriculture (USDA) Rural Urban Continuum Codes | [underlined: County Level] | Non-metro | - Urban population of 20,000 or more, adjacent to a metro area
U.S. Department of Agriculture (USDA) Rural Urban Continuum Codes | [underlined: County Level] | | - Urban population of 20,000 or more, not adjacent to a metro area
U.S. Department of Agriculture (USDA) Rural Urban Continuum Codes | [underlined: County Level] | | - Urban population of 2,500 to 19,999, adjacent to a metro area
U.S. Department of Agriculture (USDA) Rural Urban Continuum Codes | [underlined: County Level] | | - Urban population of 2,500 to 19,999, not adjacent to a metro area
U.S. Department of Agriculture (USDA) Rural Urban Continuum Codes | [underlined: County Level] | | - Completely rural or less than 2,500 urban population, adjacent to a metro area
U.S. Department of Agriculture (USDA) Rural Urban Continuum Codes | [underlined: County Level] | | - Completely rural or less than 2,500 urban population, not adjacent to a metro area
Veteran's Affairs (VA) | [underlined: County Level] | | The VA system of urban/rural classification combines those of the census blocks following census tracts urbanized areas and those of county population density.
Veteran's Affairs (VA) | [underlined: County Level] | Urban | - Urban nucleus of 50,000 or more people which may or may not contain any individual cities of 50,000 or more, but must have a core with a population density of 1,000 persons per square mile and may contain adjoining territory with at least 500 persons per square mile.
Veteran's Affairs (VA) | [underlined: County Level] | Rural | - Those counties not falling into the extremes of Urban or Highly Rural
Veteran's Affairs (VA) | [underlined: County Level] | Highly Rural | - Counties with an average population density of 7 residents per square mile
US Dept of Agriculture Rural Urban Commuting Area codes (RUCA) | [underlined: Census Tract Level] | | RUCA is a 33 code system which defines rural areas in terms of census tracts based on population density in an “urban area” combined with primary and secondary commuter flow rates. Census tracts can be converted to a ZIP code approximation. Operationalization of this classification system typically involves grouping these codes into larger categories. The most common grouping uses a 4 tier system including Urban Areas, Large Rural Towns, Small Rural Towns, and Isolated Rural Towns. Below are the various versions and their data sources over time.; - Version 1.1 - First publicly released RUCA files. Based on 1998 ZIP code areas and 1990 Census commuting data. Data are not available.; - Version 1.11 - ZIP code correction made in Oregon file.; - Version 2.0 - Based on 2004 ZIP code areas and 2000 Census commuting data.; *An additional 2.0 version based on 2006 ZIP code areas and 2000 commuting data is also available.
US Dept of Agriculture Rural Urban Commuting Area codes (RUCA) | [underlined: Census Tract Level] | Urban Areas | - ZIP codes or census tracts that have Metropolitan cores as defined by the OMB
US Dept of Agriculture Rural Urban Commuting Area codes (RUCA) | [underlined: Census Tract Level] | Large Rural Towns | - ZIP codes or census tracts with Micropolitan cores and substantial commuting patterns to urban clusters
US Dept of Agriculture Rural Urban Commuting Area codes (RUCA) | [underlined: Census Tract Level] | Small Rural Towns | - ZIP codes or census tracts with primary commuting flows to or within population centers of between 2,500 and 9,999 residents
US Dept of Agriculture Rural Urban Commuting Area codes (RUCA) | [underlined: Census Tract Level] | Isolated Rural Towns | - ZIP codes or census tracts in less populated rural areas with no primary commuting flows to Urbanized Areas or Urban Clusters
U.S. Census Urban Rural Definitions | [underlined: Population Density] | | [underlined: 2000 census criteria] All territory, population, and housing units located within an urbanized area (UA) or an urban cluster (UC). It delineates UA and UC boundaries to encompass densely settled territory, which consists of:; - core census block groups^*^ or blocks that have a population density of at least 1,000 people per square mile and; - surrounding census blocks that have an overall density of at least 500 people per square mile; “Rural” therefore consists of all territory, population, and housing units located outside of UAs and UCs. Geographic entities, such as census tracts, counties, metropolitan areas, and the territory outside metropolitan areas, often are “split” between urban and rural territory, and the population and housing units they contain often are partly classified as urban and partly classified as rural. [underlined: 1990 census criteria] All territory, population, and housing units in urbanized areas and in places of 2,500 or more persons outside urbanized areas. More specifically, “urban” consists of territory, persons, and housing units in:; 1. Places of 2,500 or more persons incorporated as cities, villages, boroughs (except in Alaska and New York), and towns (except in the six New England states, New York, and Wisconsin), but excluding the rural portions of “extended cities.”; 2. Census designated places of 2,500 or more persons.; 3. Other territory, incorporated or unincorporated, included in urbanized areas.
U.S. Census Urban Rural Definitions | [underlined: Population Density] | Urbanized Area | - An urbanized area consists of a central city and surrounding areas whose population is > 50,000. They may or may not contain individual cities with 50,000 or more; rather, they must have a core with a population density generally exceeding 1,000 persons per square mile; and may contain adjoining territory with at least 500 persons per square mile (other towns outside of an urbanized area whose population exceeds 2,500).
U.S. Census Urban Rural Definitions | [underlined: Population Density] | Rural Area | - Rural areas comprise open country and settlements with fewer than 2,500 residents; areas designated as rural can have population densities as high as 999 per square mile or as low as 1 person per square mile.
US Dept of Agriculture Urban Influence Codes | Population Density and proximity to urban areas | | - Urban Influence Codes (2003) divide the 3,141 US counties into 12 groups combing both population density and proximity to urban areas.
US Dept of Agriculture Urban Influence Codes | Population Density and proximity to urban areas | Metro counties | - Divided into “large” areas with at least 1 million residents and “small” areas < 1 million residents.
US Dept of Agriculture Urban Influence Codes | Population Density and proximity to urban areas | Nonmetro [underlined: micropolitan counties] | - Divided into three groups: adjacent to a large metro area, adjacent to a small metro area, and not adjacent to a metro area.
US Dept of Agriculture Urban Influence Codes | Population Density and proximity to urban areas | Nonmetro [underlined: noncore] counties | - Divided into seven groups by: 1). their adjacency to metro or micro areas and 2) whether or not they have a town/village of at least 2,500 residents.

* Census block group (BG) - an area normally bounded by visible features, such as streets, streams, and railroads, and by non-visible features, such as the boundary of an incorporated place.