# EVIDENCE TABLES

Appendix C, Table 1 Preventive Care/Ambulatory Care Sensitive Conditions

Author, Year, Study Design | Study Population (Sample Size, Inclusion/Exclusion, Region/Nationwide) | Data Source, Year(s) (if applicable) Response Rate (if applicable) | Definition of Urban/Rural | Covariates | Confidence Score^*^ | Results^**^
Casey, 2001^18^ Cross-sectional | N = 130,452 respondents Exclusion: respondents whose BRFSS records could not be linked to ARF data using county Federal Information Processing Standard (FIPS) codes Nationwide | National data from the 1997 Behavioral Risk Factor Surveillance System (BRFSS) and the 1999 Area Resource File | Urban = Metropolitan Statistical Area (MSA) Rural adjacent: nonmetropolitan county physically adjacent to metropolitan Rural nonadjacent county | Age, gender, education, Income, race/ethnicity, insurance coverage, primary care physicians/1000 population, census region | High | Influenza vaccination in the past year for women ≥ 65 years old (-) Pneumonia vaccination for women ≥ 65 years old (-)
Epstein, 2009^27^ Cross-sectional | N = 1,508 Inclusion: stratified random sample of 200 women who gave birth to a live child 60-100 days before selection date Oregon | 2003 Oregon Pregnancy Risk Assessment Monitoring System Oregon Birth Certificate database Response: 65.8% | Rural-Urban Commuting Area Codes: urban, large rural, or small/isolated rural | Age, marital status, education, Hispanic ethnicity, intended or unintended pregnancy, household income, questionnaire language | Low/Moderate | Late initiation of prenatal care (-) Barriers to prenatal care initiation (-)
Laditka, 2009^28^ Cross-sectional | Inclusion: counties with ≥ 1,000 for analyses of children and adults <65 yrs; counties with ≥ 500 for analyses of adults 65+ Colorado, Florida, Kentucky, Michigan, New York, North Carolina, South Carolina, and Washington | Hospital discharge data for 2002 from State Inpatient Databases (SIDS); Area Resource File (2002); U.S. Census Bureau; U.S. Census Bureau's Small Area Health Insurance Estimates | 2003 Urban Influence Codes (U.S. Department of Agriculture) with 7 levels from large metro to most rural | Hospital bed supply, hospitals with EDs, health maintenance organization penetration, presence of community health center or rural health center, race, education, population density, unemployment, state fixed effects | Moderate | Hospitalizations for ambulatory care sensitive conditions – ages 18 to 64 (+); R>U Hospitalization for ambulatory care sensitive conditions – ages 65 and older (+); R>U
Saag, 1998^29^ Cross-sectional | N = 787 Inclusion: home-dwelling elderly (age > 65 years), ≥ 1 of the indicator conditions, resident of state's 12 most rural and 10 most urban counties Iowa | Population based phone survey evaluating six common chronic indicator conditions (arthritis, hypertension, cardiac disease, diabetes mellitus, peptic ulcer disease, and chronic obstructive pulmonary disease) Response: 57% | U.S. Department of Agriculture continuum codes. Urban: metro areas with > 250,000 residents Rural: <2,500 residents in a single incorporated place and not adjacent to metro areas | Age, gender, education beyond high school, living on a farm, alcohol use, smoking in the past, medical advice needed in the past year, supplemental private insurance, medication coverage, Medicaid, VA clinic in the past year, Distance from physician, congregate meals, Use of Meals on Wheels, Homemaker service | Low | Continuity of care (seeing same physician) (+); R>U Appointments with specialists (+); R>U Perceived need for medical advice (+); R<U
Schreiber, 1997^30^ Cross-sectional | N = 1,461 Zip Codes with population >300 New York | New York State Department of Public Health; U.S. Census Bureau 1990 | Six point urban-rural scale based on population, size of largest city/town, % of workforce that commutes outside the county; grouped to New York City area, upstate New York urban-suburban, and more remote rural | % of population in poverty, population density (population per square mile, % blacks, number of primary care physicians per 1,000 population), location of ZIP code (within 8 miles of hospital, within a health professional shortage area [HPSA]) | Low | Ambulatory Care Sensitive Conditions (ACSC) admissions:; a. increased as population density decreased within each of the 3 defined regions (+); b. increased as percentage of black residents increased (+) except in the most rural group (-); c. increased as number of primary care physicians per 1000 increased (+)
Zhang, 2000^19^ Cross-sectional | N = 4,051 Inclusion: men and women aged 65 or older Nationwide | 1994 National Health Interview Survey (NHIS) Overall response: 79.5% | U.S. Office of Management and Budget's (MSAs and non-MSAs) | Census region, education, household income, insurance status, overall health status | Moderate | Flu shots received in previous year (-)

* See Methods section for explanation

** U=Urban; R=Rural; HR=Highly rural; F=Frontier; S=Suburban; (+)=difference statistically significant; (-)=difference not statistically significant

Appendix C, Table 2 Cancer Screening

Author, Year Study Design | Study Population (Sample Size, Inclusion/Exclusion, Region/Nationwide) | Data Source, Year(s) (if applicable) Response Rate (if applicable) | Definition of Urban/Rural | Covariates | Confidence Score^*^ | Results^**^
Brown K., 2009^20^ Cross-sectional | N = 1,922 women (620 rural) Inclusion: Non-Hispanic whites and non-Hispanic black, age ≥40, reporting screening mammography or no mammography Tennessee | Behavioral Risk Factor Surveillance System (BRFSS) 2001 and 2003 | Rural-Urban Continuum Codes (RUCCs) – collapsed to 2 levels: rural or urban | Age, race/ethnicity, marital status, education, employment, health status, smoker, health insurance, personal health care provider | Moderate | Screening mammography utilization (-)
Casey, 2001^18^ Cross-sectional | N = 130,452 respondents Exclusion: respondents whose BRFSS records could not be linked to ARF data using county Federal Information Processing Standard (FIPS) codes; California data on mammograms and (Pap) tests (state had modified wording of those questions) | National data from the 1997 Behavioral Risk Factor Surveillance System (BRFSS) and the 1999 Area Resource File | Urban = Metropolitan Statistical Area (MSA) Rural adjacent = nonmetropolitan county physically adjacent to metropolitan Rural nonadjacent county | Age, gender, education, income, race/ethnicity, insurance coverage, primary care physicians/1000 population, census region | High | Colon cancer screening for women and men age ≥50 (+); U>all R Cervical cancer screening for women age > 18 (+); U>all R Mammogram for women age ≥50 (+); U>non-adjacent R
Coughlin, 2008^23^ Cross-sectional | N = 97,820 (Pap smears), 91,492 (mammography) Inclusion: reported county of residence Pap smears-women with known Pap test status, ≥18 yrs, no history of hysterectomy Mammography-women with known mammography screening status, ≥40 yrs Nationwide excluding Alaska, including District of Columbia | Behavioral Risk Factor Surveillance System (BRFSS) 2002 Area Resource Files (ARF) 2004 Census 2002 | US Department of Agriculture (USDA) RUCC collapsed to 3 levels: rural, suburban, metropolitan | Individual-level covariates (e.g., age, race, marital status, education, income, employment, health insurance, health status) and contextual covariates (e.g., residence, number of health centers per population, number of physicians per population) | High | Pap test in counties with <300 primary care providers per 100,000 women (+); U>R, U>S Pap test in counties with 300-500 physicians per 100,000 women (+); U>S Mammogram (+); U>R, S>R
Coughlin, 2004^22^ Cross-sectional | N = 23,565 men and 37,847 women, age ≥ 50 yrs Nationwide | Behavioral Risk Factor Surveillance System (BRFSS) 1998-1999 | USDA RUCC collapsed to 3 levels: rural, suburban, metropolitan | Race/ethnicity, age, gender, education, health insurance, visit to physician in past year, health profile, shortage area | High | Fecal occult blood test in past year (+); U>R, S>R Sigmoidoscopy or colonoscopy in past 5 years (+); U>R
Coughlin, 2002^21^ Cross-sectional | N = 108,326 women, age ≥ 40 yrs (mammography and clinical breast examination) N=131,813 women, age ≥ 18 yrs, with no history of hysterectomy (Pap testing) Nationwide | Behavioral Risk Factor Surveillance System (BRFSS) 1998-1999 | USDA Beale Codes collapsed to 3 levels: metropolitan, suburban, rural | Age, gender, race, education, number of people in household, health status, visit to physician in past year, marital status | High | Mammogram in past 2 years (+); U>R, U>S, S>R Pap test in past 3 years (+); U>R
Kinney, 2006^24^ Case-control | N = 558 cases and 952 controls (matched on race, age, and gender) Inclusion (cases): ages 50-80 yrs, pathologically confirmed invasive adenocarcinoma of colon North Carolina | Interviews (face-to-face) 1996-2000 Response: 72% (cases), 62% (controls) | U.S. Census Bureau 1990 standards Urban: Metropolitan Statistical Area (1 city with ≥50,000 or total metro area of ≥100,000) Rural: non-metropolitan | Age, race, gender, education, poverty index, recent colorectal cancer screening | Moderate | Colon cancer screening (NR); U>R# # Unadjusted analysis
Schootman, 1999^25^ Cross-sectional | N = 7,200 women Inclusion: Primary breast or cervical carcinoma diagnosed 1991-95, non-institutionalized, ≥18 yrs old Iowa | Behavioral Risk Factor Surveillance System (BRFSS) 1996-97 Surveillance, Epidemiology, and End Results (SEER) 1991-95 Response: 39% | Based on number of residents per square mile; 5 levels <20, 20-29, 30-39, 40-99, or 100 or more res/mi^2^; urban=more than 100 res/mi^2^ | Breast cancer screening model: income, having health insurance Cervical cancer screening model: education, age, income, having health insurance | Moderate | Breast cancer screening (+); U>R Cervical cancer screening (+); U>R
Stearns, 2000^26^ Cross-sectional | N = 12,637 Inclusion: Medicare enrollee for whole year, living in household for whole year Nationwide | Medicare Current Beneficiary Survey (MCBS) 1993 | 1993 Urban Influence Codes (UIC); 9 categories collapsed to 5 for this study | Age, gender, race, Medicaid status, income, education, living arrangement, health status, functional status, provider supply | Moderate | Mammogram in last year (-) (except rural county with city of >10,000 < urban) Pap test in last year (-)
Zhang, 2000^19^ Cross-sectional | N = 8,970 (Pap smears), 2,729 (mammography), 4,051 (flu shots) Inclusion: completed all three sections of NHIS Three services: Pap smears in past 3 years for women 18-65 yrs, mammogram in past 2 years for women-50-69 yrs, flu shot in past year for people ≥65 yrs Nationwide | U.S. National Health Interview Survey (NHIS) 1994 Response: 80% | Metropolitan Statistical Areas (MSA); urban county is within MSA; rural is all other non-metropolitan counties | Education, household income, health insurance status, Census region | Moderate | Pap smear (-) Mammogram (-)

* See Methods section for explanation

** U=Urban; R=Rural; HR=Highly rural; F=Frontier; S=Suburban; (+)=difference statistically significant; (-)=difference not statistically significant; (NR)=significance not reported

Appendix C, Table 3 Cancer Care

Author, Year, Study Design | Study Population (Sample Size, Inclusion/Exclusion, Region/Nationwide) | Data Source, Year(s) (if applicable) Response Rate (if applicable) | Definition of Urban/Rural | Covariates | Confdence Score^*^ | Results^**^
Chirumbole, 2009^36^ Cross-sectional | N = 10,414 cases (pancreatic), 56,767 (colorectal) Inclusion: colorectal or pancreatic cancer Pennsylvania | Pennsylvania Department of Health, Bureau of Health Statistics Research 2000-05 US Census Bureau 2000 American Medical Association Physician-Related Data Resources | US Census Bureau; grouped 67 counties into 22 Workforce Investment Areas (WIA); rurality variable was % of a WIA population that was rural | Age, gender, insurance status, education, poverty status, race, number of physicians per 100,000, ratio of oncology physicians to primary care physicians | Low | Later stage at diagnosis:; - Pancreatic (+); U>R; - Colorectal (-)
Elliott, 2004^35^ Data collected as part of group-randomized trial of intervention directed at rural providers | N = 2,568 (1,463 or 57% rural) Inclusion: pathologically confirmed incident cancers of breast, colon, rectum, lung, or prostate; age ≥18 yrs, resided and had primary care physician in one of 18 rural study communities, spoke English, accrued within 6 weeks of diagnosis Lake Superior region (Minnesota, Wisconsin, Michigan) | Health Care Records 1992-97 | U.S. Census Bureau | Age, oncology consultation | Low/Moderate | Proportion of cases staged at diagnosis:; - (+); U>R for breast, non-small cell lung, and prostate cancer; - (-); colorectal and small cell lung cancer; Stage at diagnosis:; - (+); R>U for breast, colorectal, and non-small cell lung cancer; - (-); small cell lung or prostate cancer; Initial management score:; - (+); R<U for all cancers; Clinical trial participation:; - (+); R<U for colorectal and prostate cancer; Surveillance testing score:; - (+); R<U lower breast and colorectal cancer; - (-); for lung and prostate cancer
Higginbotham, 2001^37^ Cross-sectional | N = 9,685 cancer cases Inclusion: incident cancer cases (primary cancer site) Mississippi | Mississippi State Department of Health Central Cancer Registry and Division of Vital Statistics 1996 | Census data: county with more than 50% rural designated as rural | Age | Moderate | Cancer incidence (-) Cancer mortality (-) Cancer staged at diagnosis :; - (+); U>R, all sites; - (+); U>R; women; - (+); U>R; African Americans (except lung cancer); Advanced stage at diagnosis (+); R>U all sites and lung cancer
Kinney, 2006^24^ Case-control | N = 558 cases and 952 controls (matched on race, age, and gender) Inclusion (cases): ages 50-80 yrs, pathologically confirmed invasive adenocarcinoma of colon North Carolina | Interviews (face-to-face) 1996-2000 Response: 72% (cases), 62% (controls) | U.S. Census Bureau, 1990 Urban: Metropolitan Statistical Area (1 city with ≥50,000 or total metro area of ≥100,000) Rural: non-metropolitan | Age, race, gender, education, poverty index, sampling probabilities | Moderate | Colon cancer stage at diagnosis (-)
Loberiza, 2009^34^ Retrospective cohort | N = 2,330 Inclusion: lymphoma complete prognostic clinical data, residential ZIP code Patients with lymphoma reported to the Nebraska Lymphoma Study Group (Nebraska and surrounding states) | University of Nebraska Medical Center Oncology Database 1982-2006 | Rural-Urban Commuting Area code; collapsed to 2 categories Providers classified as university-or community-based | Median household income, distance traveled, year of treatment | Low/Moderate | Risk of death (-); risk greater for rural community treated patients than urban or rural university treated patients; in high-risk subgroup risk higher for all groups relative to urban university treated Advanced treatment (-); use was higher in University-treated compared to community treated regardless of residence Death from primary lymphoma (+); R>U
McLafferty, 2009^39^ | N = 150,794 cases Inclusion: breast, colorectal, lung, or prostate cancer; staged cases Illinois | Illinois State Cancer Registry 1998-2002 Surveillance, Epidemiology, and End Results (SEER) staging data | Rural-Urban Commuting Areas: modified to create Chicago city, Chicago suburb, other metropolitan, large town, and rural | Multiple models; 1. unadjusted; 2. age, race; 3. socioeconomic and access variables based on zip code | Moderate | Risk of late stage diagnosis:; - Model 1 (+); city > all other regions for all 4 cancers (except lung cancer in suburb); - Model 2 (+); city > all other regions for colorectal, breast (except city similar to most rural), and lung (except city similar to suburb) cancers; city > suburb (only) for prostate cancer; - Model 3 (+); city >other metro and large town for breast, city > large town for colorectal, and city >all regions except suburb for lung cancers
McLaughlin, 2009^41^ Nested case-control | N = 453 patients Inclusion: continuous Medicaid enrollment, newly started on aromatase inhibitor or tamoxifen, hormone receptor-positive tumors, stage I-III breast cancer, started adjuvant hormonal monotherapy during study, female, ≥55 yrs, white or African American North Carolina | Linked North Carolina Central Cancer Registry-Medicaid Claims data 2000-04 | US Census Bureau and US Department of Health and Human Services- urban or rural | Tumor size, type of surgery, race, type of provider and practice setting, admitted to hospital, admitted to nursing facility, receiving home health care, age | Low/Moderate | Treatment with aromatase inhibitors (+); U>R
Paquette, 2007^38^ Cross-sectional | N = 129,811 (colorectal), 161,479 (lung) Inclusion: all adults (≥20 yrs) in SEER database with primary colorectal or lung cancer Nationwide | Surveillance, Epidemiology, and End Results (SEER) database (National Cancer Institute), 2000-03 | Rural-Urban Continuum Codes (RUCCs) – 9 levels collapsed to: rural (levels 7 and 9) or urban (levels 1 to 3) | Age, race, language isolation, gender, marital status, income | Moderate | Unstaged cancer rates:; - Colorectal (+); R>U; - Lung (+); R>U#; Stage IV at presentation:; - Colorectal (+); U>R; - Lung (+); U>R; # Unadjusted analysis
Sankaranarayanan, 2009^40^ | N = 6,561 cases Inclusion: incident colorectal cancer, age ≥19 yrs, no missing data in registry Nebraska | Nebraska Cancer Registry 1998-2003 Surveillance, Epidemiology, and End Results (SEER) staging data | Office of Management and Budget (OMB) 2003 definitions: urban metropolitan, micropolitan nonmetropolitan, rural nonmetropolitan | Age, gender, race/ethnicity, marital status, education, income, insurance, anatomic site | Moderate/High | Early stage at diagnosis (+); Micropolitan>R (metropolitan no different from rural)
Schootman, 1999^25^ Cross-sectional | N = 7,200 women Inclusion: primary breast or cervical carcinoma diagnosed 1991-95, non-institutionalized, ≥18 yrs old Iowa | Behavioral Risk Factor Surveillance System (BRFSS) 1996-97 Surveillance, Epidemiology, and End Results (SEER) 1991-95 Response: 39% | Based on number of residents per square mile; 5 levels <20, 20-29, 30-39, 40-99, or 100 or more res/mi^2^; urban=more than 100 res/mi^2^ | Age | Moderate | In situ breast cancer rate (NR); R<U Invasive cervical carcinoma (NR); R>U Breast or cervical cancer mortality (-)
Schootman, 2001^42^ Cross-sectional | N = 6,988 (502 [7%] rural) Inclusion: women, all ages, diagnosed with primary microscopically confirmed DCIS 1991-1996, treated with breast conserving surgery 9 metropolitan areas and 5 states across U.S. | Surveillance, Epidemiology, and End Results (SEER) program Area Resource File (ARF) | Metropolitan Statistical Area | SEER registry, year of diagnosis | Moderate | Receipt of radiation therapy:; - Age <65 yrs (+); R<U; - Age 65+ (-)
Shugarman 2008^33^ | N = 26,073 (84.2% urban, 6.3% large rural, 4.9% small rural, 4.6% isolated rural) Inclusion: continuously enrolled Medicare beneficiaries, age 65+, first diagnosed cancer was lung cancer 1995-99 Exclusion: enrolled in managed care, end-stage renal disease, eligible for Medicare due to disability 14 registries nationwide | SEER data linked to Medicare claims Area Resource File | Rural-urban commuting area (RUCA codes) – 30 codes collapsed to 4 categories: urban, large rural city, small rural town, isolated small rural town | Gender, race/ethnicity, age at diagnosis, median ZIP code income, comorbidities, number of subspecialists, number of hospitals, residing in health professional shortage area, residing in census tract with >15% non-fluent English speakers | Moderate | Mortality (-) Unstaged at diagnosis (-) Stage at diagnosis (-) Number of subspecialists (+); R<U Receipt of radiation therapy (trend); R<U

* See Methods section for explanation

** U=Urban; R=Rural; HR=Highly rural; F=Frontier; S=Suburban; (+)=difference statistically significant; (-)=difference not statistically significant; (NR)=significance not reported

Appendix C, Table 4 Diabetes/End Stage Renal Disease (ESRD)

Author, Year, Study Design | Study Population (Sample Size, Inclusion/Exclusion, Region/Nationwide) | Data Source, Year(s) (if applicable) Response Rate (if applicable) | Definition of Urban/Rural | Covariates | Confidence Score^*^ | Results^**^
Andrus, 2004^47^ Non-RCT | N = 187 Inclusion: type II diabetes, two or more visits to their clinic in the past 12 months (Rural = 78, Urban = 109) Alabama | Medical records of patients seen in clinics between January and August 2001 Data collection took place Aug-Sept 2001 in Rural clinic; and Feb-March 2002 in urban clinic | Not defined other than rural family practice clinic was a “physician-owned private family practice clinic with one physician provider” and urban internal medicine clinic included five physicians specializing in internal medicine and one physician specializing in endocrinology | None | Very Low | Preventive care consistent with American Diabetes Association guidelines (NR); R<U# Blood pressure, lipid, and HbA1c goals met (NR); R<U# # Unadjusted analysis
Koopman, 2006^48^ Cross-sectional | N = 947 Inclusion: US civilian, ≥20 years, non-institutionalized, participated in NHANES III: household adult, examination, and laboratory data files Exclusion: did not participate in all three parts of the survey Nationwide | Third National Health and Nutrition Examination Survey (NHANES III) 1988-1994 | Urban: MSA Rural: Non-MSA | Gender, age, BMI, perceived health status, income, insurance status, education, usual place of care, # times seeing physician in past year, duration of diabetes | Moderate | Undiagnosed diabetes (-) Uncontrolled BP (+); RHispanics>UHispanics Glycemic control (-) Cholesterol control (-)
Krishna, 2010^45^ Cross-sectional | BRFSS (N = 441,351) MEPS (N = 48,428) Inclusion: age 18 and older Nationwide | Behavioral Risk Factor Surveillance System (BRFSS) 2001-2002; Medical Expenditure Panel Survey (MEPS) 2001-2002. | Urban: MSA Rural: Non-MSA | Age, BMI, insurance coverage, gender, race/ethnicity, education, region of country, income, personal physician | Moderate/High | Prevalence of diabetes (+); R>U Compliance with diabetes care guidelines for eye exam, foot exam, diabetes education (+); R<U based on BRFSS (-); based on MEPS (eye and foot exam only) Compliance with guidelines for HbA1c test (-)
Morden, 2010^49^ Cross-sectional | N=11,688 Inclusion: Veterans with diabetes Nationwide | 2005 national Veterans Health Administration cardiometabolic quality of care random sample chart review SMITREC: VA Serious Mental Illness Treatment and Evaluation Center | RUCA categories; - RUCA 1: urban; - RUCA 2: large rural city/town; - RUCA 3: small/isolated rural town | Mental disorder diagnosis, RUCA (1-3), age, gender, race (black/non-black), marital status, substance abuse diagnosis, Charlson comorbidity index score, # VA outpatient visits, # visits to a VA community-based outpatient clinic, VA cost share category | Moderate/High | LDL, foot exams, eye exams, renal testing, HbA1c, blood pressure (-)
O'Hare, 2006^44^ Cross-sectional | N = 552,279 (and 4,363 dialysis facilities) Inclusion: initiated dialysis between 1/1/95 and 12/31/02 and survived >90 days without transplant Nationwide | U.S. Renal Data System 2000 U.S. Census CMS Dialysis Facilities Compare database | Rural-Urban Commuting Area Codes (RUCA):; - Urban area; - Large Rural Area; - Small Rural Area; - Remote, Small Rural Area | Age, gender, comorbid conditions at start of dialysis, dialysis modality at 90 days; ZIP code per capita income and % >25 yrs with high school diploma Stratified for race/ethnicity | High | Survival (+); all R white non-Hispanic > U white non-Hispanic; remote small R white Hispanic < U white Hispanic; small R and remote small R black > U black Time to kidney transplant (+); all R white non-Hispanic > U white non-Hispanic; large R and small R black < U black; remote small R Native American > U Native American
Rosenblatt, 2001^50^ Cross-sectional | N = 30,589 Inclusion: all fee-for-service Medicare (continuous coverage) patients, 65+ years, alive at the end of the 1994, 2+ physician encounters for diabetes care in 1994, all medical care in Washington Washington state | Medicare Part B claims data 1994 | RUCA subset:; - Urban; - Adjacent Large; - Rural; - Remote Large Rural; - Adjacent Smalll; - Remote Small | Sociodemographic factors, comorbidities, provider specialty | Moderate | Glycated hemoglobin test (+); Adjacent large R<all other locations (+); Large remote > all others
Ward, 2009^48^ Cross-sectional | N = 18,377 (from 1,681 ZIP codes with analysis by ZIP) Inclusion: age ≥ 20 years, treated incident end-stage renal disease (ESRD) attributed to diabetes or autosomal dominant polycystic kidney disease (ADPCKD) 1/1/01 to 6/30/04, California resident California | U.S. Renal Data System^*^, 2000 U.S. Census, California Office of Statewide Health Planning and Development^*^, U.S. Dept of Health and Human Services Health Resources^*^ *1/1/01 to 6/30/04 | U.S.D.A Rural-Urban Commuting Area Codes; 10 levels collapsed to rural (codes 9, 10) or urban (codes 1-8) | Socioeconomic status (income, proportion with income <200% of poverty level, house value, rent, education, % college graduates), insurance status, hospitalization for hypoglycemic events, rural location | Low | Annual incidence of ESRD attributed to diabetes (-) Annual incidence of ESRD attributed to autosomal dominant polycystic kidney disease (-)
Weingarten, 2006^51^ Cohort | Inclusion: fee-for-service Medicare beneficiaries with diabetes, ages 18-75, enrolled for prior 12 months with ≥23 months of continuous Part B coverage, ≥ 1 inpatient or emergency visit or 2 outpatient visits ≥7 days apart Exclusion: gestational diabetes, died during measurement period Nationwide | CMS National Diabetes Database (Part of Medicare Health Care Quality Improvement Program) 1999-2001 Participants identified from Part A and Part B claims data | County codes from the Federal Information Processing Standards; based on urban-rural continuum codes – 9 codes collapsed to 3: Urban, Semi-rural (adjacent to metropolitan area), Rural (not adjacent) | Race (white/non-white), ethnicity (Hispanic/non-Hispanic), states (Census divisions) | Low | Indicator rate^*^; A. in 10 top performing states (many in northern and eastern regions of US): 1 of 10 SR<U, 3 of 10 SR>U; 2 of 10 R<U, 2 of 10 R>U; B. in 10 lowest performing states (many in south): 9 of 10 SR<U, 1 of 10 SR>U; 7 of 10 R<U, 1 of 10 R>U; *Indicator rate = Annual HbA1c measurement; Biennial lipid profile; Biennial eye exam

* See Methods section for explanation

** U=Urban; R=Rural; SR=Semi-rural; (+)=difference statistically significant; (-)=difference not statistically significant; (NR)=significance not reported

Appendix C, Table 5 Cardiovascular Disease

Author, Year, Study Design | Study Population (Sample Size, Inclusion/Exclusion, Region/Nationwide) | Data Source, Year(s) (if applicable) Response Rate (if applicable) | Definition of Urban/Rural | Covariates | Confidence Score^*^ | Results^**^
Colleran, 2007^55^ Cross-sectional | N = 200 Inclusion: 50 + years old, seen more than once at the study sites (1 urban academic medical center, 1 rural community clinic) in the previous year New Mexico | Medical record review; randomly selected charts to include 50 patients with cardiovascular disease (CVD) (25 Hispanic, 25 non-Hispanic white) and 50 without CVD from each site | Not defined other than “urban academic medical center”, “rural community clinic” | Age, gender, hypertension, diabetes, dyslipidemia, smoking status | Low | Standard medications for treatment of CVD (+); U>R# Cholesterol lowering medications (+); U>R# Attainment of blood pressure goal (+); U>R# Attainment of LDL goal (-)# # Unadjusted analysis
Dellasega, 1999^56^ Case Reports | N = 32 Inclusion: Patients from tertiary care center serving 31 counties, 65+ years old, primary diagnosis a medical or surgical cardiac condition, cognitively intact, being discharged to home Pennsylvania | Patient medical records; phone survey post-discharge to 20 weeks Survey Response: 32/50 completed all five surveys (60%) | Pennsylvania Dept of Aging Rural Services Task Force seven designations: Philadelphia, Allegheny, urban, suburban, semi-urban, semi-rural, and rural (based on population density and proximity to major metropolitan area) | Age, gender, marital status, education, number of hospitalizations, severity of illness | Very Low | Number of medications at discharge and during follow-up (+); U>R with more fluctuations in medications in urban patients Number of cardiac medications at discharge and during follow-up (+); U>R General Health SF-36 scale (NR); R improved over time, U decreased over time
Hicks, 2010^53^ Cross-sectional | N = 778 surveys Inclusion: Provider completed survey after patient encounter, non-pregnant adult with type 2 diabetes 26 practices in Colorado (13 urban; 13 rural) | Provider questionnaire, June 2003-May 2004 Response: not stated | Rural: community of fewer than 25,000 residents at least 32 km (20 mi) from a major metropolitan center | Age, gender, race, ethnicity, BP (near goal or uncontrolled), practice level, communication problems, income level, number of prescription medications | Moderate | Provider taking action if BP was poorly controlled (-) Number of medications (+); R>U
King, 2006^54^ Cross-sectional | N = 300 Inclusion: outpatient, diagnosed hypertension (100 from an urban, a suburban, and a rural clinic) South Carolina | Medical record review; consecutive sample | Not defined other than “urban university family practice center”, “suburban residency practice”, “rural private practice” clinics | Age, race, gender, number of medications, number of visits in past 12 months, comorbidities | Very Low | Blood pressure control (+); R>U
Morden, 2010^49^ Cross-sectional | N = 23,780 Inclusion: Veterans with hypertension (approximately 1/3 with mental disorder [MD]) Nationwide | 2005 national Veterans Health Administration cardiometabolic quality of care random sample chart review SMITREC: VA Serious Mental Illness Treatment and Evaluation Center | RUCA categories; - RUCA 1: urban; - RUCA 2: large rural city/town; - RUCA 3: small/isolated rural town | Mental disorder diagnosis, RUCA (1-3), age, gender, race (black/non-black), marital status, substance abuse diagnosis, Charlson comorbidity index score, # VA outpatient visits, # visits to a VA community-based outpatient clinic, VA cost share category | Moderate/High | Blood pressure control (-)

* See Methods section for explanation

** U=Urban; R=Rural; (+)=difference statistically significant; (-)=difference not statistically significant; (NR)=significance not reported

Appendix C, Table 6 HIV/AIDS

Author, Year, Study Design | Study Population (Sample Size, Inclusion/Exclusion, Region/Nationwide) | Data Source, Year(s) (if applicable) Response Rate (if applicable) | Definition of Urban/Rural | Covariates | Confidence Score^*^ | Results^**^
Cohn, 2001^58^ Cohort | N = 3,173 (367 rural) Inclusion: HIV-infected adults who received care from January through June, 1996 Contiguous United States | HIV Cost and Services Utilization Study (HCSUS) 1996; rural component | Urban: MSA or New England county metropolitan areas Rural: non-MSA Office of Budget and Management, 1992 | Age, gender, race, ethnicity, risk group behavior, education, insurance, household income, region of care, CD4 count, HIV provider type | Moderate/High | Appointments with providers caring for more HIV-infected patients (+); urban care > rural care^#^ Use of pneumocystis carinii pneumonia medication (+); urban care > rural care^#^ Use of highly-active antiretroviral therapy (HAART) (+); urban care > rural care
Napravnik, 2006^59^ Cross-sectional | N = 1,404 Inclusion: 18+ years, attended ≥ 1 clinic appointment at a Univ. of North Carolina HIV clinic between 1/1/2000 and 12/31/2002 Southeastern United States (predominantly North Carolina) | Patient medical records from the University of North Carolina HIV outpatient clinic | Rural: MSA with < 50,000 inhabitants | Age, gender, race/ethnicity, insurance status, distance to clinic, clinical AIDS diagnosis, CD4 cell count, time since entry into HIV care | Moderate | Average number of clinic visits per year (-)^#^
Schur, 2002^60^ Cohort | N = 275 rural patients Inclusions: HIV infected adults, receiving care from sampled providers (≥ 1 visit in early 1996) Exclusions: patients seen by military, prison, or emergency department providers Contiguous United States | HIV Cost and Services Utilization Study (HCSUS) 1996 American Medical Association MasterFile of physicians | Urban: MSA Rural: non-MSA Office of Budget and Management, 1992 | Age, gender, race/ethnicity, risk group, clinical stage, annual income, insurance status, CD4 count | Moderate | 73.6% of rural residents received HIV care in urban setting^#^ Older patients more likely to receive care in rural area (+)^#^
Whyte, 1992^57^ Cohort | N = 308 AIDs cases Inclusion: female residents of Georgia aged 13 and older at time of diagnosis whose cases were reported by 12/31/90 Georgia | Centers for Disease Control and Prevention (1983-1990) Office of Vital Statistics (Georgia), March 1991 | Metro Atl: residents of 8 counties of metropolitan Atlanta Other Areas: residents of remaining counties | Race, mean age, mode of infection | Very Low | Median survival time (+); Metro>Other^#^ Probability of surviving 90 days (+); Metro>Other^#^

* See Methods section for explanation

** U=Urban; R=Rural; (+)=difference statistically significant; (-)=difference not statistically significant; (NR)=significance not reported

# Unadjusted results

Appendix C, Table 7 Neurologic Conditions

Author, Year, Study Design | Study Population (Sample Size, Inclusion/Exclusion, Region/Nationwide) | Data Source, Year(s) (if applicable) Response Rate (if applicable) | Definition of Urban/Rural | Covariates | Confidence Score^*^ | Results^**^
Buchanan, 2006b62 Cohort | N = 1,518 Inclusion: Member of the National Multiple Sclerosis (MS) Society Exclusion: none Nationwide | Phone interview, Oct 2004 – Jan 2005 Response: 31% | Urban: Metropolitan Statistical Area (MSA) Adjacent Rural Area: <50 miles from MSA More Remote Rural Area: >50 miles from MSA | None | Very Low | Saw neurologist in past year (+); U>MRR^#^ Wanted to see neurologist but did not (+); MRR>U, AR>U^#^ Majority of MS care from primary care physician (+); MRR>U^#^
Buchanan, 2006a61 Cohort | N = 1,518 Inclusion: Member of the National Multiple Sclerosis Society Exclusion: none Nationwide | Phone interview, Oct 2004 – Jan 2005 Response: 31% | Urban: Metropolitan Statistical Area (MSA) Adjacent Rural Area: <50 miles from MSA More Remote Rural Area: >50 miles from MSA | None | Low/Very Low | Taking disease-modifying medications (+); U>MRR^#^ Discontinued disease-modifying medications because of other medical side effects(+); AR>U^#^ Discontinued disease-modifying medications because of out-of-pocket expense (+); AR>U^#^
Buchanan, 2006c63 Cohort | N = 1,518 Inclusion: Member of the National Multiple Sclerosis Society Exclusion: none Nationwide | Phone interview, Oct 2004 – Jan 2005 Response: 31% | Urban: Metropolitan Statistical Area (MSA) Adjacent Rural Area: <50 miles from MSA More Remote Rural Area: >50 miles from MSA | None | Very Low | Need for mental health care in past 12 months (+); AR<U, MRR<U^#^ No insurance coverage for mental health care (+); AR>U, MRR>U^#^ No providers in area or too far to visit (+); AR>U^#^
Wilson, 2009^66^ Cross-sectional | N = 1,427 counties or county sets (contiguous, single state sets of counties merged to achieve population >50,000) Inclusion: all US counties or county sets except Alaska, Hawaii, and 12 cities with changes in county definitions between 1980 and 2000 Nationwide | Numbers of rehabilitation therapists (physical [PT] or occupational [OT] therapists, speech-language pathologists [SLP]) from 1980 and 1990 ARF and 2000 EEO Health Professional Shortage Area Data | US Office of Management and Budget (OMB) – metropolitan (metro): central county with ≥1 urbanized area and outlying counties economically tied to core county | None | Moderate/High | PTs, OTs, or SLPs per 100,000 residents (NR); U>R^#^ PTs, OTs, or SLPs per 100,000 residents (NR); Non-shortage area > partial or total shortage area^#^
Johnstone, 2002^65^ Cross-sectional | Data on numbers of providers of services to people with traumatic brain injury Missouri | U.S. Census Bureau, 2000; Office of Social and Economic Data Analysis, 2000; Rural Policy Research Institute, 2000; Missouri State Board of Registration for the Healing Arts, 1999; American Board of Professional Psychology; Missouri Brain Injury Association, 2000 | Office of Management and Budget (OMB) designations of Metropolitan and Non-metropolitan (MSA or non-MSA) | None | Moderate/High | Physicians (NR); U>R^#^ Physiatrists (NR); U>R^#^ Nurses (NR); U=R^#^ Rehabilitation Therapists (NR) U>R^#^ Mental Health (NR); U>R^#^
Schootman and Fuortes, 1999^64^ Cross-sectional | N = 292 patients age 18+ years with TBI sustained July-Dec 1996 Iowa | Survey sent to persons identified through the Iowa Central Registry for Brain and Spinal Cord Injuries, January, 1998 Response: 57.4% (292 is subset – those 18 years and older) | Population density (residents/square mile) – 5 levels <20, 20-29, 30-39, 40-99, 100+ | Injury severity, age, gender, type of respondent (injured person vs. proxy), inability to see a doctor because of cost | Low | Functional dependence (+); most urban > non-urban Perceived need for services (-)

* See Methods section for explanation

** U=Urban; R=Rural; MRR=More Remote Rural; AR=Adjacent Rural; (+)=difference statistically significant; (-)=difference not statistically significant; (NR)=significance not reported

# Unadjusted analysis

Appendix C, Table 8 Mental Health

Author, Year, Study Design | Study Population (Sample Size, Inclusion/Exclusion, Region/Nationwide) | Data Source, Year(s) (if applicable) Response Rate (if applicable) | Definition of Urban/Rural | Covariates | Confidence Score^*^ | Results^**^
Severe Mental Health
Farrell, 1996^72^ Cross-sectional | N = 4,930 Inclusion: adults discharged from 8 public psychiatric hospitals to 1 of 40 community mental health centers (CMHC, 23 rural, 17 urban) in 1992 Virginia | Questionnaire (completed by CMHC staff), 1992 Inpatient Database Questionnaire completion rate: 97% (94% linked to database) | State mental health authority definition -rural is <120 people/sq mi | None | Moderate | Continuity of care (+); R>U as indicated by a. CMHC had record of discharge, b. CMHC contacted patient during hospitalization, c. patient and CMHC had contact after discharge, d. CMHC provided face-to-face services, and e. composite score# # Unadjusted analysis
Fischer, 2008^73^ Cohort | N = 258 (121 or 47% rural; included veterans) Inclusion: ages 18-67, schizophrenia, mental health service utilization records available for at least 18 months Arkansas | Interviews with patients (consumers) and family, friends, or providers who knew patient well (informants) 1992-99 | Office of Management and Budget – Urban: Metropolitan Statistical Area (MSA) Rural: non-MSA | Insight into illness, cognitive functioning, age, gender, ethnicity | Moderate | Irregular vs. regular outpatient mental health service use (+); R>U Comorbid substance abuse effect on mental health service use (+); less effect on patients with family support at least weekly
Mohamed, 2009^75^ Cohort | N = 5,221 veterans (4,373 urban) Inclusion: participant in mental health intensive case management (MHICM) program Nationwide | Clinical process assessments by MHICM staff after veteran's 1^st^ 6 months in MHICM program, FY2000-FY2005 VA Outpatient Encounter File | Rural-Urban Commuting Codes – 4-groups: urban (U), large rural city (LR), small rural town (SR), or isolated rural (R) community | None | Moderate | Patient contact (+); R<U# Receipt of services (+); all R<U Psychotherapy, substance abuse treatment, crisis intervention, medication management, screening or care for medical problems, rehabilitation, vocational support, housing support # # Unadjusted analysis
Rost & Owen, 1998^76^ Cohort NOTE: telephone interviews with randomly selected adults in 11,078 households; 998 screened positive for depression | N = 54 (46 with 12 month follow-up) Inclusion: ≥18 yrs; screened positive for depression (telephone); not bereaved, manic, or acutely suicidal; lifetime mania identified in face-to-face interviews Arkansas | Telephone and face-to-face interviews 1992-93 Response: 85% of eligible after face-to-face interview with complete data (interview at 1 yr) | Urban: Metropolitan Statistical Area (MSA) Rural: non-MSA | Age, gender, education, health insurance, marital status, minority status, income, recent manic symptoms, severity of depression, previous psychiatric hospitalizations, recent drug/alcohol problems, psychiatric co-morbidity, physical condition | Low | During 12 month follow-up:; a. any non-acute mental health service (-); b. seen in general medical setting only (+); R>U; c. any acute services for physical or mental health (+); R>U; d. suicide attempt (-); e. manic episode (+); R>U; f. depressive symptoms (-)
Hospitalization
Fortney 2007^70^ Cross-sectional | N = 811 counties Inclusion: 551, 529 depression related hospitalizations, age 20+ 14 states nationwide | Statewide Inpatient Database (SID), 2000 Census Bureau Dept. of Agriculture Health Resources and Services Administration | Urban Influence Codes (UIC) – 12 categories | Ethnicity, poverty level, education, income, employment, housing stress, county economy source, number of providers, number of hospital beds, penetration rate of HMOs, shortage area, geographic location | Low/Moderate | Hospitalization rate (+); most U>all other UIC categories (5 comparisons were significant)
Fortney 2009^71^ Cross-sectional | N = 811 counties Inclusion: 1443,107 schizophrenia related hospitalizations, age 20+ 14 states nationwide | Statewide Inpatient Database (SID), 2000 Census Bureau Dept. of Agriculture Health Resources and Services Administration | Urban Influence Codes – 12 categories U.S. Office of Management and Budget – MSA/non-MSA | Ethnicity, poverty level, education, income, employment, housing stress, county economy source, providers, hospital beds, penetration rate of HMOs, shortage area, geographic location | Low/Moderate | Hospitalization rate (+);most U>all other UIC categories (8 comparisons were significant)
Depression
Fortney, 1999^74^ Cohort | N = 106 of original 470 with depression visit in 6 months after baseline interview, complete data set, and provider in Arkansas (see Rost 1999) Arkansas | See Rost 1999 Records from providers, insurers, and pharmacies identified Geocoded addresses for travel time | Used travel time | Age, gender, ethnicity, employment status, education, severity of depression, physical and psychiatric comorbidities, insurance coverage, treatment sector | Low/Moderate | Number of visits (+); increased travel time associated with fewer visits Guideline concordant treatment (+); increased travel time associated with reduced odds of guideline concordant treatment
Rost, 2007^78^ Cross-sectional (combining data from 2 studies) | N = 1,455 (304 rural) Inclusion: primary care patients with depression (excluded schizophrenia and bipolar disorder) 11 states | 2 studies in Quality Improvement for Depression database (through 1999):; 1. Partners in Care (PIC), 46 practices (3 rural), 5 states (35% agreed to participate; follow-up 89% at 2 yr); 2. Quality Enhancement by Strategic Teaming (QuEST), 12 practices (4 rural), 10 states (73% agreed to participate, follow-up 70% at 2 yr) | Practices designated as urban (MSA) or rural (non-MSA) | Age, gender, minority status, education, marital status, employment, depression, psychiatric or physical comorbidity, antidepressant use, social support, stressful life events | Low | Baseline characteristics:; a. use of outpatient care (specialty, medical) - past 6 mos (-)#; b. antidepressant use - past 6 mos (-)#; c. any hospitalization - past 6 mos (-)#; Hospitalization for physical problems in 6 months after baseline (+); R>U whether or not they received specialty care during those 6 months Hospitalization for emotional problems (+); R>U at 18 months # Unadjusted analysis
Rost, 1999^77^ Cross-sectional NOTE: telephone interviews with randomly selected adults in 11,078 households; 998 screened positive for depression | N = 434 (286 rural) of original 470 with 12 month data Inclusion: ≥18 yrs; screened positive for depression (both telephone and face-to-face interviews); not bereaved, manic, or acutely suicidal Arkansas | Telephone and face-to-face interviews 1992-93 Response: 74% of eligible after screening agreed to face-to-face interview; 92% with complete data | Census data 1990, rural defined as non-metropolitan | Age, gender, education, health insurance, marital status, minority status, employment status, income, living alone, health insurance, severity of depression, physical and psychiatric comorbidity | Moderate | Any outpatient treatment for depression (-) Type of outpatient treatment for depression (-) Quality of outpatient depression treatment (-) Outpatient specialty care visits for depression (+); R<U Outpatient general medicine visits for depression (-) Change in depression severity (-) Hospitalization for physical problems (+); R>U Hospitalization for mental health problems (-)
Rost & Zhang, 1998^69^ Cross-sectional | See Rost 1999 | See Rost, 1999 | Census data 1990, rural defined as non-metropolitan | See Rost, 1999 | Moderate | Outpatient services for physical problems (-) Outpatient services for mental health other than depression (-) Hospitalizations for physical or mental health problems 1-6 months after baseline (+); R>U Hospitalizations in months 7-12 (-) Suicide attempts (+); R>U
Post Traumatic Stress Disorder (PTSD)
Elhai, 2004^79^ Cross-sectional | N = 100 veterans (52 rural) Inclusion: male, diagnosed with PTSD at outpatient clinic Southeastern United States | Medical chart review (date not reported) | U.S. Census data 1990 | Service use adjusted for distance and driving time | Very Low | Service use (PTSD clinic, primary care, and specialty care visits) within 1 year after initial PTSD evaluation (-) Dissociative Experiences Scale score (+); R>U MMPI-2 clinical scales (-)
Substance Abuse
Booth, 2000^80^ Cohort | N = 733 Inclusion: current adult drinkers (18+) who met DSM-IV criteria for alcohol abuse or dependence in the past year or were at risk for meeting DSM-IV diagnostic criteria in the following year Six southern states (AL, AR, GA, LA, MS, TN) | Telephone interview Response: 76% (baseline); 90% and 82% of baseline completed interview at 6 and 12 months, respectively | Census Bureau Definitions of MSA; rural is non-MSA | Gender, ethnicity, age, income, health insurance, average time to provider, days to see MD for advice about drinking, acceptability of treatment, social support, alcohol abuse (past 6 months), alcohol dependence (past 6 months), lifetime drug use, Axis I DIS diagnosis (past 6 months), antisocial personality disorder, social consequences of drinking, negative life events, chronic medical problems, prior treatment for alcohol problems | Moderate/High | Twelve month alcoholism treatment use (-)
Fortney et al., 1995^84^ Cohort | N = 4,621 Inclusion: adult (18+) male veterans completing inpatient alcoholism treatment at VA Alcohol Dependency Treatment Program (ADTP) 33 VA inpatient ADTPs | VA Patient Treatment File, 1987 | Small community (outside an MSA); metropolitan area (MSAs with < 3 million inhabitants); large metropolitan area (MSAs with > 3 million inhabitants) | Distance to VA medical center, age, marital status, illness severity, race | Moderate | Attendance at outpatient appointment for alcoholism treatment 30 days after discharge from inpatient ADTP (+); small community > metropolitan, large metropolitan < metropolitan
Grant, 1996^81^ Cross-sectional | N = 42,862 Inclusion: non-institutionalized adults (18+) Nationwide | National Longitudinal Alcohol Epidemiological Survey, 1992 Response: 97.4% (person); 91.9% (household) | Not provided | Gender, age, ethnicity, education, marital status, family history of alcoholism, past alcohol disorder and treatment, health insurance, employment, income, children < 14 at home, spouse/partner with alcoholism, onset and severity of alcoholism, daily alcohol intake, major depression, comorbid drug use disorder; illicit drug use in past year | Moderate | Odds of entering treatment in the past year for drinking-related problems (-)
Metsch & McCoy, 1999^82^ Cross-sectional | N = 2,222 Inclusion: age 18+, self-reported drug use ≤30 days prior to recruitment; no active drug treatment 30 days prior to intake Two sites in Florida: Miami (urban) and Immokalee (rural) | In-person interview Response: not reported | Not defined Immokalee characterized as an unincorporated area known for agriculture and cattle industries | None | Low/Moderate | Ever in drug-user treatment (+); U>R# Length of prior treatment (+); U>R# Treatment in past 24 months (+); U>R# Attempted but unable to get treatment in past 12 months (+); U>R# Of those using treatment, use of outpatient treatment (-)# # Unadjusted analysis
Robertson & Donnermeyer, 1997^83^ Correlational | N = 3,629 (497 who used an illegal substance in the past year) Inclusion: age 21+, non-institutionalized, living in residential type of interest Nationwide | National Household Survey on Drug Abuse, 1991 Response: not reported | Rural defined as places with <2,500 inhabitants outside of or not next to urban areas (1980 Census) 3 residential types: metropolitan-rural (rural area within MSAs); non-metropolitan-rural; non-metropolitan-urban | NONE???? For this outcome | Low | 5.6% of nonmetropolitan-rural drug users sought treatment compared with 6.6% of the remaining respondents
Suicide
Fiske, 2005^68^ Cross-sectional | N = 41 county clusters (counties of <100,000 grouped with neighboring counties) California (all counties) | California Departments of; a. Health Service, Center for Health Statistics, 1993-2001 (odd years); b. Finance (population data); c. Consumer Affairs (providers) | U.S. Census Bureau; urbanicity of county based on proportion of county residents living in an urbanized area or town with population of ≥2,500 | Age | Low | Suicide rate (+); R>U Interaction between urbanicity and number of providers (-) (no association with suicide rate)
Gibbons, 2005^67^ Cross-sectional | N = 91,673 Inclusion: all individuals who committed suicide Nationwide | National Vital Statistics (CDC) 1996-98 (suicide rates) IMS Health, Inc (antidepressant medication prescriptions) | Based on county population | Model 1: Age, gender, race Model 2: Added income Model 3: Added county mean drug prescription for each class of drugs | Low | Suicide rate (NR); smaller population counties>larger population counties Ratio of non-tricyclic antidepressants to tricyclic antidepressants (NR); larger population counties>smaller population counties
Utilization
Hauenstein, 2006^87^ Cross-sectional | N = 32,319 Inclusion: civilian, non-institutionalized, 18-64 yrs Nationwide | Medical Expenditure Panel Survey (MEPS), 1996-2000 data Response: 73%-78% (varied by panel) | Rural-Urban Continuum Codes 1994; collapsed to metropolitan, non-metropolitan least rural, or non-metropolitan most rural | Gender, age, income-to-needs ratio, schooling, geographic region, mental health, physical health, marital status, number of children, usual source of care, insurance type, year | Moderate | Any mental health visit (+); U>most R and least R>most R for women Specialized mental health visit (+) U>most R for women and men
Petterson, 2009^86^ Cross-sectional | N = 36,288 Inclusion: civilian, non-institutionalized, ≥18 yrs; non-Hispanic white, African American, Mexican American Nationwide | Medical Expenditure Panel Survey (MEPS) 1996-2000 data Response: 73%-78% (varied by panel) | Rural-Urban Continuum Codes 1994; collapsed to metropolitan, non-metropolitan least rural, or non-metropolitan most rural | Self-reported mental and physical health, gender, age, education, employment status, marital status, income-to-needs ratio, health insurance | Moderate | Receipt of any mental health service:; - (+); African American < non-Hispanic white in any location; - (+); Mexican American < non-Hispanic white, urban and least rural non-MSA only; Receipt of specialty mental health service:; - (+) African American < non-Hispanic white in urban and least rural locations; - (+) Mexican American <non-Hispanic white in Urban location only
Petterson, 2003^85^ Cross-sectional | N = 2,381 Inclusion: ≥ 1 visit of any mental health treatment during calendar year, civilian, non-institutionalized, 18-64 yrs Nationwide | Medical Expenditure Panel Survey (MEPS) 1996-98 data Response: 78% | Rural-Urban Continuum Codes 1993; collapsed to metropolitan or nonmetropolitan | Gender, race/ethnicity, age, education, employment status, marital status, income-to-needs ratio, health insurance, mental health, physical health | Moderate | Any or specialized mental health visit:; - (+); U>R if reported mental health was good or fair#; - (-) if reported mental health was poor#; Mental health care use (-); trend for U>R Ever hospitalized in calendar year (-) Ever saw a medical doctor (-) Primarily saw a medical doctor (-) # Unadjusted analysis
Wang, 2005^88^ Cross-sectional | N = 9,282 (interviewed) Inclusion: ages 18+, English speaking Nationwide | National Comorbidity Survey Replication (NCS-R), 2001-2003 (face-to-face interviews) Response: 71% | U.S. Census Bureau, 2000; large (≥ 2 million) and small central city, large (≥ 2 million) and small suburbs or central city, adjacent area, rural area | Age, gender, race/ethnicity, education, marital status, family income, health insurance | Moderate/High | Odds of receiving any mental health treatment in prior 12 months (+); rural<all non-rural Odds of receiving specialty mental health treatment in prior 12 months (+); rural<all non-rural except suburb <2 million Mental health treatment adequacy:; - (+); rural>all non-rural for mental health specialty treatment; - (-); any service use, general medical, and non-health care treatment

* See Methods section for explanation

** U=Urban; R=Rural; (+)=difference statistically significant; (-)=difference not statistically significant; (NR)=statistical significance not reported

Appendix C, Table 9 Use of Medication

Author, Year, Study Design | Characteristics of Study Population (Sample Size, Inclusion/Exclusion, Region of United States) | Data Source and Year(s) of Sampling (if applicable) Response rate (if applicable) | Definition of Urban/Rural | Covariates | Confidence Score^*^ | Results^**^
Dellasega, 1999^56^ Prospective/Longitudinal | N = 32 Elderly patients admitted to a large tertiary care center for cardiac condition. Specific inclusion criteria: 1) 65 or older; 2) has medical or surgical cardiac condition as primary diagnosis; 3) cognitively intact; 4) being discharged from hospital Pennsylvania | Medical records and telephone interviews Response rate: 50% | Seven-level county designations established by the Pennsylvania Department of Aging Rural Services Task Force merged into two categories (i.e., rural vs. urban) | Age, gender, severity of illness | Low | Number of medications (+); U>R
Fillenbuam, 1993^89^ Correlational | N = 3,973 Individuals 65 or older who are identified as black or white Piedmont area of North Carolina | Duke Established Populations for Epidemiologic Studies of the Elderly, 1986-1987 Response rate: 80.3% (black); 87.2% white | U.S. Census Bureau Definition | Gender, marital status, age, education, functional status, medical status, self-rated health, number of medical visits in past year, continuity of care, overnight hospitalization in past year, insurance status, income | Low/Moderate | Medication use - elderly whites (+);U>R Medication use - elderly blacks (-)
Hanlon, 1996^90^ Cross-sectional | N = 4,110 Individuals 65 or older who are identify as black or white Piedmont area of North Carolina | Duke Established Populations for Epidemiologic Studies of the Elderly, 1986-1987 Response rate: 80.3% (black); 87.2% white | U.S. Census Bureau Definition | Age, race, gender, education, functional status, number of functional limitations, chronic disease status, number of health visits in past year, hospitalization in past year, continuity of care, Medicaid status | Low/Moderate | Prescription medication use (+); U>R Number of non-prescription medications (+); U>R Use of non-prescription medications (-)
Lago, 1993^91^ Cross-sectional | N = 18,641 Elderly enrolled in the Pennsylvania Pharmaceutical Assistance Contract for the Elderly (PACE) Pennsylvania | Claims data for PACE beneficiaries, 1984-1988; Medicare health services records; County-level demographic and health services resources databases | Human Resources Profile County Code from 1980 census data in Area Resource File (ARF; 10 levels depicting degree of rurality) | Age; gender; race; income; marital status; physicians, pharmacies, hospital beds, and nursing home beds per 1,000 population; outpatient physician visits; any physician visits, inpatient days, or any hospital day in past month | Moderate | Monthly claims(-); HR, U
Lillard, 1999^92^ Cross-sectional | N = 910 Medicare enrollees ages 66 or older Excluded individuals covered by HMOs or institutionalized National | 1990 Elderly Health Supplement to the Panel Study of Income Dynamics (PSID), a nationally representative telephone/mail survey Response rate: 99% (telephone survey); 74%(mail survey) | Area Resource File (Department of Health and Human Services) | Age, gender, race, marital status, education, income, current health status, insurance status | Low | Twelve-month medication use: (-) Prescription cost (+); U>R
Mueller, 2004^93^ Cross-sectional | N = 32,465,895 Noninstitutionalized Medicare beneficiaries 65 or older National | 1997 Medicare Current Beneficiary Survey; 1996 Medical Expenditure Panel Survey | Rural: any place of residence not in a Metropolitan Statistical Area (MSA) | Insurance status | Low/Moderate | Total drug expenditures (-) Prescriptions filled (+); R>Uninsured U Prescriptions filled (+): Insured R>insured U
Rogowski, 1997^95^ Cross-sectional | N = 996 Noninstitutionalized Medicare enrollees ages 66 or older National | Panel Study of Income Dynamics (PSID), 1990 Response rate: 99% (telephone survey); 74% (mail survey) | Rural: any place of residence not in a MSA | Age, education, gender, race, marital status, income, insurance status, health status | Low | Percentage of family income spent on medications (-)
Xu, 2003^94^ Cross-sectional | N = 3,498 Noninstitutionalized elderly West Texas | Telephone survey, 2000 Response rate: 71% (phase 1); 89.3% (phase 2); 53.2% (both phase 1 and 2) | Urban (counties in MSA) Rural (counties outside MSA or population < 50,000) Frontier (counties with < 7 people/square mile) | Race, age, gender, employment, income, insurance, usual source of care, physical and mental health-related quality of life, several health beliefs | Low | Odds of prescription drug use (-) R, U; (+) U>F Usual pharmacy (-) R,U; (+) U>F e

* See Methods section for explanation

** U=Urban; R=Rural; HR=Highly rural; F=Frontier; (+)=difference statistically significant; (-)=difference not statistically significant

Appendix C, Table 10 Medical Procedures and Diagnostic Tests

Author, Year, Study Design | Characteristics of Study Population (Sample Size, Inclusion/Exclusion, Region of United States) | Data Source and Year(s) of Sampling (if applicable) Response rate (if applicable) | Definition of Urban/Rural | Covariates | Confidence Score^*^ | Results^**^
Escarce et al., 1993^97^ Cross-sectional | N = 1,204,022 Inclusion: Medicare enrollees 65+ years Exclusion: end-stage renal disease, covered by an HMO National | Health Care Finance Administration (HCFA) Medicare Part B Annual Data Beneficiary File, 1986 HCFA Health Insurance Skeleton Eligibility Write-off File, 1986 | Rural: living in a nonmetropolitan county Urban: living in a metropolitan county | Age, gender | Low | Rurality and race interaction (+); white-black relative risks for services were higher in rural areas for 12 of 32 studied services (including 8 of 14 outpatient services)
Miller et al., 1995^96^ Cross-sectional | N = 31,100,000 Medicare Part B beneficiaries Excluded those enrolled in HMOs National | Medicare Part B Annual Data File, 1990 Health Insurance Eligibility Write-off File, 1990 | Rural areas are the non-MSA areas of states. Urban areas are subdivided into small MSAs (less than 250,000 inhabitants), large MSAs (250,000 to 3 million), and very large MSAs (3 million or more). | Age, race, gender | Low | Physician utilization (+); R<U (particularly consultations, psychiatric visits, emergency department visits, imaging services, and laboratory tests)

* See Methods section for explanation

** U=Urban; R=Rural; (+)=difference statistically significant; (-)=difference not statistically significant

Appendix C, Table 11 Medical Appointments with Providers

Author, Year, Study Design | Characteristics of Study Population (Sample Size, Inclusion/Exclusion, Region of United States) | Data Source and Year(s) of Sampling (if applicable) Response rate (if applicable) | Definition of Urban/Rural | Covariates | Confidence Score^*^ | Results^**^
Blazer, 1995^98^ Cross-sectional | N = 4,162 (4,001 respondents) Inclusion: ages 65+ years; resident of 1 of 5 counties 1 urban and 4 rural counties in North Carolina | Duke Established Populations for Epidemiologic Studies of the Elderly, 1986-1987 Response rate: 80% | US Bureau of the Census: rural is county with fewer than 2,500 inhabitants Also classified counties as rural or urban | Race/ethnicity, self-rated health, the health index, age, gender, education, marital status, employment status, income, Medicare coverage, Medicaid coverage, private insurance | Low/Moderate | Ambulatory care visits (-)
Fortney, 2002^105^ Cross-sectional | N = 355,452 Inclusion: primary care patients treated at 38 Community-Based Outpatient Clinics (CBOCs) or 32 parent VA Medical Centers (VAMCs) CBOCs and VAMCs from 16 Veterans Integrated Services Networks (VISNs) | Austin Automatic Center (AAC) outpatient file, 1995-1998 | Comparisons focused on CBOCs vs. VAMCs | Age, gender, marital status, ethnicity, service-connected, percent service connected, VA service use in prior year | Moderate | Primary care encounters (+); CBOC>VAMC Specialty care encounters (+); CBOC<VAMC Number of days to follow-up care for hospitalization or inpatient psychiatric treatment (-)
Glover, 2004^100^ Cross-sectional | N = 50,993 (9,778 or 19% rural) Inclusion: ages 18-64 Nationwide | National Health Interview Surveys, 1999-2000 Response: 81% (1999) and 83% (2000) | Urban: Metropolitan Statistical Area Rural: Non-MSA | Race/ethnicity, gender, age, region of residence, interview language, limitations in activities, self-reported health status, education, employment, family size, income, marital status, insurance | Moderate | Health care use in past 12 months (-) (within urban and rural, minorities less likely to have visit (+))
Himes & Rutrough, 1994^101^ Cross-sectional | N = 11,101 Inclusion: non-institutionalized persons ages 65 and older Nationwide | National Health Interview Survey (Supplement on Aging), 1984 | Four categories: Metropolitan central city residents (within SMSAs); metropolitan noncentral city residents; nonmetropolitan nonfarm residents (outside SMSA); nonmetropolitan farm residents | Age, gender, ethnicity, marital status, education, health status, limitations in activities of daily living, living arrangement, poverty, region of U.S., bed disability days | Moderate | Physician visit in past year (+); non-metro<metro
Larson & Fleishman, 2003^102^ Cross-sectional | N = 14,997 Inclusion: persons 18+ in second round interviews Exclusion: missing data for the independent variables, or died, became institutionalized, or moved out of the country in 1996 Nationwide | Medical Expenditure Panel Survey, 1996 | Nine-category Urban Influence Codes: Large MSA with 1million or more; small MSA with less than 1 million; adjacent large MSA with city of 10K or more; adjacent large MSA with city less than 10K; adjacent small MSA with city of 10K or more; adjacent small MSA with city less than 10K; not adjacent with city of 10K or more; not adjacent with city between 2.5-10K; non-adjacent with no town more than 2.5K | Gender, ethnicity, education, age, insurance, family income, self-reported health, priority condition, limitations in activities of daily living or instrumental activities of daily living, physician availability, region, has usual source of care | Moderate | Any ambulatory care visit (+); adjacent large MSA (with city <10k or > 10k) < MSA with ≥ 1million Any ambulatory care visit (-): most rural vs. most urban Number of ambulatory care visits (+); most rural < large MSA
Maciejewski, 2007^104^ Cross-sectional | N = 63,478 Inclusion: primary care patients treated at one of 108 Community-Based Outpatient Clinics (CBOCs) and/or one of 72 parent VA Medical Centers (VAMCs) | VA FY2000 Outpatient Care File; VA FY2000 Patient Treatment File; VA FY2000 and FY2001 Decision Support System Outpatient and Inpatient National Extracts | Compared VAMC patients, CBOC patients, and crossover patients | Age, gender, race, marital status, eligibility for free care, service-related disability, DCG risk score, distance to usual source of care | High | Primary care visits (+); CBOC>VAMC Specialty care visits (+); CBOC<VAMC Total outpatient expenditures (+); CBOC<VAMC
McConnel & Zetzman, 1993^99^ Cohort | N = 3,350 Inclusion: individuals 55 and older Exclusion: died, moved, could not be re-interviewed, or had missing data on relevant variables Nationwide | National Center for Health Statistics' Longitudinal Study of Aging, 1984-1986 Area Resource File, 1987 | U.S. Department of Agriculture (1989) 10-level County Adjacency Codes to create three categories: major urban (MSA counties), less urban (non-MSA counties with towns larger than 2.5K), and rural (non-MSA counties with towns with fewer than 2.5K) | Age, gender, ethnicity, living arrangement, social contact, education, prior service use, Medicaid eligibility, limitations in activities of daily living, health status, chronic conditions, and availability of hospital beds, physicians, and nursing home beds. | Low | Use of physician services (-)
Mueller, 1998^103^ Cross-sectional | N = 112,246 Inclusion: respondents under 65 Nationwide | National Health Interview Survey, 1992 Response rate: 95.7% | Urban: central or noncentral cities located within a MSA Rural: outside a MSA, either on a farm or not | Age, gender, self-reported health status, presence of acute or chronic health problems, ethnicity, family size, education, insurance status, income, region of country | Moderate | Physician visit in past 12 months:; - (+); any R<U White (except R African American)
Saag et al., 1998^29^ Cross-sectional | N = 787 Inclusion: home-dwelling elderly (age > 65 years), ≥ 1 of the indicator conditions, resident of state's 12 most rural and 10 most urban counties Iowa | Population based phone survey evaluating six common chronic indicator conditions (arthritis, hypertension, cardiac disease, diabetes mellitus, peptic ulcer disease, and chronic obstructive pulmonary disease) Response: 57% | U.S. Department of Agriculture continuum codes. Urban: metro areas with > 250,000 residents Rural: <2,500 residents in a single incorporated place and not adjacent to metro areas | Age, gender, education beyond high school, living on a farm, alcohol use, smoking in the past, medical advice needed in the past year, supplemental private insurance, medication coverage, Medicaid, VA clinic in the past year, Distance from physician, congregate meals, Use of Meals on Wheels, Homemaker service | Low | Number of physician visits (-)
Weeks et al., 2005^8^ Cohort | N = 67,985 (1997); 51,899 (1998); 56,833 (1999) Inclusion: male veterans 65 years or older and enrolled in Medicare fee-for-service plans New England | VHA's Patient Treatment File and Outpatient Clinic File, 1995-1999 Medicare Denominator, 100% MEDPAR, Outpatient, and Physician Supply files, 1997-1999 | Department of Agriculture Rural/Urban Commuting Area (RUCA) Code; grouped into urban (RUCA codes 1-6) and rural (RUCA codes 7-10) | Age, gender, living in the northern or southern states of New England, number of VHA and Medicare inpatient admissions | Moderate | Primary, specialist, and mental health visits (+); R<U (across all three study years)

* See Methods section for explanation

** U=Urban; R=Rural; HR=Highly rural; F=Frontier; (+)=difference statistically significant; (-)=difference not statistically significant

Appendix C, Table 12 Usual Source of Care

Author, Year, Study Design | Study Population (Sample Size, Inclusion/Exclusion, Region/Nationwide) | Data Source, Year(s) (if applicable) Response Rate (if applicable) | Definition of Urban/Rural | Covariates | Confidence Score^*^ | Results^**^
Meza, 2006^106^ Cross-sectional | N = 3,871 Inclusion: Department of Defense beneficiaries, active duty, uniformed services Nationwide | Health Care Survey of DoD Beneficiearies (HCSDB) – mailed survey 2002 Response: 29% | US Census Bureau – metropolitan (metro), adjacent to metropolitan (adj), or nonadjacent (non adj) | Age, service category, marital status, self-reported health status, race, rank, gender, utilization, years in health plan, health plan, indicator of other health plan | Low | Rating of health plan, rating of health care, getting care quickly (+); Adj or non-adj> Metro Getting needed care (+); Metro>Adj or non-adj
Blazer, 1995^98^ Cross-sectional | N = 4,162 (2,152 or 47% rural); 4001 with complete data Inclusion: >65 yrs, resident of 1 urban or 4 rural counties North Carolina | Stratified (race & residence) random sample-Duke Established Populations for Epidemiologic Study of the Elderly survey, 1986-87 Response: 80% | US Bureau of the Census Rural: fewer than 2,500 inhabitants Also classified counties as rural or urban | Race/ethnicity, self-rated health, health index, age, gender, education, marital status, employment, income, Medicare and Medicaid coverage, private insurance | Low/Moderate | Usual source of care (-) Usually sees same provider(+); R>U Put off care due to not knowing where to go (-) Put off care due to transportation diffculties (-) Put off care due to cost (+); R>U
Borders, 2004^107^ Cross-sectional | N = 2,097 Inclusion: community dwelling, age ≥65, Hispanic or non-Hispanic white West Texas | Telephone survey Response: 53% | Rural: county with fewer than 50,000 persons Frontier: county with fewer than 50,000 persons and fewer than 7 persons/mi^2^ | Age, gender, ethnicity, marital status, education, economic factors, insurance, chronic conditions | Low/Moderate | Always/usually see personal doctor/nurse (-) Always/usually able to obtain care without a long wait (-)
Glover, 2004^100^ Cross-sectional | N = 50,993 (9,778 or 19% rural) Inclusion: ages 18-64 Nationwide | National Health Interview Surveys, 1999-2000 Response: 81% (1999) and 83% (2000) | Rural: any place of residence not in a Metropolitan Statistical Area | Race/ethnicity, gender, age, interview language, region of residence, limitation of activities, self-reported health status, education, employment, family size, income, marital status, insurance | Low/Moderate | Usual source of care (-) (in rural and urban areas Hispanic adults less likely than white adults to have usual source of care) Health care use in past 12 months (-)
Koopman, 2006^48^ Cross-sectional | N = 947 Inclusion: US civilian, ≥20 years, non-institutionalized, participated in NHANES III: household adult, examination, and laboratory data files Exclusion: did not participate in all three parts of the survey Nationwide | Third National Health and Nutrition Examination Survey (NHANES III) 1988-1994 | Urban: MSA Rural: Non-MSA | Gender, age, BMI, perceived health status, income, insurance status, education, usual place of care, # times seeing physician in past year, duration of diabetes | Moderate | Usual source of care (+); U Hispanic<R Hispanic, R White, U White# # Unadjusted analysis
Larson, 2003^102^ Cross-sectional | N = 15,518 for geographic variation N = 14,997 for regression Inclusion: non-institutionalized, civilian, age 18 and older Nationwide | Medical Expenditures Panel Survey (MEPS), 1996 Area Resource File (ARF) with Urban Influence Codes (UIC) | UICs by county – large (pop'l >1 million) or small metropolitan areas; non-metropolitan areas distinguished by adjacency and pop'l of largest city (>10,000) | Gender, ethnicity, education, age, insurance, family income, self-reported health, priority condition, limitations in activities of daily living or instrumental activities of daily living, physician availability, region, usual source of care | Moderate | Usual source of care (+); most R>most U (adj. to large MSA with city <10,000 also greater than most urban)
Rohrer, 2004^18^ Cross-sectional | N = 3,689 (1,983 or 54% rural) N,=,3,680 for usual source of care outcome Inclusion: ages 65 and older West Texas | Texas Tech 5000 telephone survey, Sept.-Dec. 2000 Response: 57% | Rural: county with population less than 50,000 | Age, gender, ethnicity, resides in continuing care, health limitations, specific diagnoses, education, income, marital status, medical skepticism, religiousness, insurance status, employment, home ownership | Low | Personal doctor or nurse (-) Usual place to go for care (-)

* See Methods section for explanation

** U=Urban; R=Rural; (+)=difference statistically significant; (-)=difference not statistically significant

Appendix C, Table 13 Provider Availability and Expertise

Author, Year, Study Design | Study Population (Sample Size, Inclusion/Exclusion, Region/Nationwide) | Data Source, Year(s) (if applicable) Response Rate (if applicable) | Definition of Urban/Rural | Covariates | Confidence Score^*^ | Results^**^
Baldwin, 1999^117^ Cross-sectional | N = 4,003 physicians (619 or 15.5% rural); 382,776 patients of those physicians Inclusion: physicians practicing in either rural or urban areas (not both); specialties with at least 10 physicians submitting claims in rural and urban locations; Medicare beneficiaries (65 and older) Washington | Medicare Part B file (billed services), 1994 Health Care Financing Administration (HCFA) provider directory Medicare beneficiary file | Rural Health Service Areas defined as physician practice addresses with ZIP codes closer to rural hospital than urban hospital | None | Low/Moderate | Family physicians most likely to practice in rural area (25%); psychiatrists (5%), cardiologists (6%), gastroenterologist (8%) least likely# Family physician age (+); R>U# Patients/physician (+); R>U# Outpatient visits/physician (+); R>U# Diagnostic scope of practice similar except: urban general surgeons >CV disorders; rural general surgeons >GI disorders and urban obstetrician-gynecologists >care for menopausal symptoms; rural obstetrician-gynecologists >diagnoses outside specialty# Procedure rates (+); R>U for family practice, internal medicine, general surgery# # Unadjusted analysis
Biola, 2009^111^ Cross-sectional | N = 4,879 from 150 rural counties Inclusion: English- or Spanish-speaking, age ≥18, lived in community for previous 12 months (1 person selected from each household reached) Southeast (AL, AK, GA, LA, MS, SC, TX, WV) | Telephone survey 2002-2003; this report focused on question: How much do you agree with the statement: ‘I feel there are enough doctors in my community?’ Response: 51% | Not reported NOTE: counties selected by project leaders; typically higher poverty and unemployment rates, larger racial-ethnic minority proportions, and higher infant mortality rates than other rural counties in the state | Age, gender, race, education, children <18 years, self-reported health, health insurance status, travel time to care, problem with cost of care, ease of getting appointment, role of physician care, number of visits in past year, satisfaction with care, confidence in doctor's abilities, county characteristics | Low | Not enough physicians (+):; a. areas with fewer physicians/pop'l > areas with more physicians/pop'l; b. travel time to care more than 30 min > travel time to care less than 30 min
Brown B, 2009^109^ Cross-sectional | N = 264 (132 self-reported rural) Primary care physician assistants (PAs) Nationwide | Web-based survey, 2008 (10 case-scenarios) Response: 49% responded; 44% analyzed | Respondents self-reported rural or urban | None | Low | Mean score on 10 question case-scenario quiz (+); R>U# PAs reporting they diagnose and treat 50-100% of skin complaints (+); R>U# Cases referred to specialist per week (-)# # Unadjusted analysis
Everett, 2009^113^ Cross-sectional | N = 6,803 (887 or 13% non-metropolitan) Inclusion: graduated from high school in Wisconsin in 1957 or one of their siblings; stated they had usual source of care in 2004-05; specified a physician assistant (PA), nurse practitioner (NP), or physician (MD) with primary care specialty as usual provider Wisconsin | Wisconsin Longitudinal Study (WLS) - telephone and mail survey 1993-94 for perceived health, 2004-05 survey defined sample and all other variables Response: 80% for graduates, 78% for siblings (telephone); 88% for graduates and 81% for siblings (mailed survey to those who did telephone interview) | Office of Management and Budget (metropolitan, micropolitan, or nonmetropolitan) | Age, gender, marital status, education, personality traits, income, insurance, perceived health, number of diagnoses | Low/Moderate | 306 (4.5%) use PA/NPs as usual source of care# PA/NP as usual source of care (+); non-metro>metro, non-metro>micro # Unadjusted analysis
Ferrer, 2007^110^ Cross-sectional | N = 34,403 Inclusion: all ages, non-institutionalized, able to link household component with office and outpatient facility face-to-face visits Nationwide | MEPS, 2004 plus information from relevant clinicians Response (to MEPS): 64% | Metropolitan Statistical Area (MSA) = urban, non-MSA = rural | Age, gender, income, insurance, race/ethnicity | Low/Moderate | Odds of visiting family physician, nurse practitioner, and physician assistant (+); non-MSA>MSA Odds of visiting general internist or non-surgical specialist (+); non-MSA<MSA
Grumbach, 2003^112^ Cross-sectional | N = 33,673 clinicians (28,053 California [CA], 5,620 Washington [WA]) Inclusion: active in patient care, no longer in training, primary self-reported specialty of family/general practice, internal medicine, pediatrics, obstetrics/gynecology California, Washington | AMA Physician Masterfile plus WA licensing board information and contacts with rural physicians (physician data) Mailed survey (non-physician data) Response: 64% (CA); 67% NPs in WA, 86% PAs in WA | CA: Medical Service Study Areas (MSSA); rural – population density <250 residents/mi^2^ with no city of ≥50,000 WA: Rural Health Service Areas (HSA) and urban public health department zones; rural – core city or town non MSA or in MSA but >30 min from population base of ≥10,000 Census data | Clinician age, gender, and race/ethnicity | Low | 22% of Physician Assistants in CA practice in rural area; 28% in WA# Odds of practicing in rural areas:; - (+) family physicians, nurse practitioners, and physician assistants more likely relative to obstetricians/gynecologists; - (+) Asian, African Americans, Latinos (CA only) less likely; - (+) females less likely; # Unadjusted analysis
Gunderson, 2006^115^ Cross-sectional | N = 539 physicians who practiced in rural Florida Inclusion: physicians who self-report treating elderly (primary care, psychiatry, surgery, specialists) Florida | Mailed survey 2003 Response: 43% | Rural: one of 33 designated rural counties in Florida, practicing in rural areas of nonrural counties by Rural Urban Commuting Area codes, or Health Resources and Services Administration list of rural ZIP codes | None | Low | 55% reported decreased or eliminated patient services in past year including mental health, (35%), vaccine administration (29%), Office-based surgeries (40%), Pap smears (24%), x-rays (24%), endoscopies (43%), and electrocardiograms (11%)# Physicians in practice where ≥65% of patients were Medicare patients were more likely to reduce or eliminate services compared to those with <28.5% Medicare patients# # Unadjusted analysis
Jones, 2008^114^ Cross-sectional | N = 254 counties Inclusion: all counties in Texas Texas | Texas Medical Board US Census Bureau, 2007 | Frontier - ≤6 people per 2.6 km^2^ | None | High | 17 counties had no licensed doctors or physician assistants# Statewide: 1 physician assistant per 13.6 physicians Frontier counties: 1 physician assistant per 2.3 physicians# # Unadjusted analysis
Laditka 2009^28^ Cross-sectional | Inclusion: all US counties Nationwide | Area Resource File, 2002 | Urban Influence Codes, 2003 | None | High | Mean primary care physician supply (per 10,000 population):; - Metropolitan: 17.8 (large), 16.9 (small); - Micropolitan: 12.3 (adj. to large metro), 13.1 (adj. to small metro); - Rural: 7.1 (adj.t o small metro), 7.2 (adj. to micro), 9.2 (not adj. to metro or micro)#; # Unadjusted analysis
Menachemi, 2006^116^ Cross-sectional | N = 308 family physicians (176 rural, 132 urban) Florida | Mailed survey Response: 42% | Rural: one of 33 designated rural counties in Florida, practicing in rural areas of nonrural counties by Rural Urban Commuting Area codes, or Health Resources and Services Administration list of rural ZIP codes | None | Low | Overall, 60% reported delivery of patient services decreased or eliminated in past year# Types of services decreased or eliminated (-) (except for office-based surgeries)# # Unadjusted analysis
Strickland, 1998^118^ Cross-sectional | N = 1,118 providers (1,079 with ZIP codes) Inclusion: nurse practitioners (NP), certified nurse midwives (CNM), physician assistants (PA) residing or practicing in Georgia Georgia | Mailed survey, 1994 Response: 62% | Metropolitan Statistical Area (MSA) = urban, non-MSA = rural | None | Low/Moderate | NPs (n=554, 31% rural): older, fewer with bachelor's degree, fewer specialty credentials, more years in health care, more solo and clinic practice settings, fewer insured patients (+); R vs. U# CNMs (n=73, 29% rural): fewer specialty credentials, more hours per week, more patients per hour (+); R vs. U# PAs (n=452, 18% rural): older, fewer with bachelor's degree, more years in health care and years as PA, more patients each hour, more clinic practice settings, fewer insured patients (+); R vs. U# # Unadjusted analysis
Wilson, 2009^66^ Cross-sectional | N = 1,427 counties or county sets (contiguous, single state sets of counties merged to achieve population >50,000) Inclusion: all US counties or county sets except Alaska, Hawaii, and 12 cities with changes in county definitions between 1980 and 2000 Nationwide | Numbers of rehabilitation therapists (physical [PT] or occupational [OT] therapists, speech-language pathologists [SLP]) from 1980 and 1990 ARF and 2000 EEO Health Professional Shortage Area Data | US Office of Management and Budget (OMB) – metropolitan (metro): central county with ≥1 urbanized area and outlying counties economically tied to core county | None | Moderate/High | PTs, OTs, or SLPs per 100,000 residents (NR); U>R^#^ PTs, OTs, or SLPs per 100,000 residents (NR); Non-shortage area > partial or total shortage area^#^

* See Methods section for explanation

** U=Urban; R=Rural; (+)=difference statistically significant; (-)=difference not statistically significant