# PEER REVIEW COMMENTS AND AUTHOR RESPONSES

REVIEWER COMMENT | RESPONSE
1. Are the objectives, scope, and methods for this review clearly described?
Yes. This is a good review. | Thank you.
Yes, although I think it will be important to highlight that this review is comparing the care of rural vs. urban patients in general, and that data for rural vs. urban veterans are even more sparse and therefore one cannot infer that rural veterans face the same disparities in care as rural non-veterans. | We agree, and have clarified this in the text.
Yes
Yes. The objectives, scope, and methods make sense and are useful for researchers, providers, and policymakers. More work of this kind is needed. It is not clear why only ambulatory care articles were included in the study selection when some of the topics were relevant beyond only ambulatory care. The repeated mention of inconsistencies and other problems related to definitions of rurality and the way “rural vs. urban” is viewed conceptually were very important. More detailed suggestions about what needs to be done to address this (e.g., how will consensus be reached) would be helpful. More explicit information is needed about the study selection, data abstractions, data synthesis, and rating of the body of evidence. It would be hard to replicate this review with the information given. | We focused on ambulatory care. Including hospital care would have made the review unwieldy and too diffusely focused. That being said, some traditionally non-ambulatory care topics were included because they were indirect indicators of ambulatory care access and/or quality (e.g., hospitalizations for ambulatory care sensitive conditions). We have further clarified our methodology in the text.
a. Yes, though the methods could be expanded. It is difficult to assess the quality or thoroughness of the search for relevant articles, as the description of the process is minimal. Data abstractions were done by “researchers trained in critical analysis of the literature,” but there is no description of the training or of the qualifications of the abstractors. There is a bit more description of the evaluative ratings of the studies that were reviewed, but no mention of who did these ratings or of any inter-rater reliability.; b. Another concern is that the tables in which you present your ratings of the quality of the studies do not seem to be reflected in the text. For example, in a table, you give two studies low confidence ratings. But in the text, there is no indication that there may be problems with those studies. As one reads the text, the only way he would know that you have doubts about the quality of these studies would be to continually refer to the table at the end of the section. Few readers will do this. Within each section of text, you might want to segregate the good studies form the bad ones so the reader will know which ones to rely most on. | These are both excellent points and we have made relevant revisions in the text.
Yes
Yes
Yes
2. Is there any indication of bias in our synthesis of the evidence?
No
No. This is a balanced and objective review that highlights the lack of good information and the inability to draw any firm conclusions. | Thank you.
No
While there is no strong indication of bias, sources of bias could be better protected against through specific efforts. The methods used for review would be strengthened by blinding reviewers to both author and journal. Inter-rater reliability could be tested by more than one reviewer reviewing the same articles. It is unclear what preparation the reviewers had and how the reviewers were instructed and trained for this purpose. The term “trained reviewer” is used several times without much explanation about what that means. There is variation in that term. | We have elaborated on the methodology in the text to address the issues raised. The first and second authors rated all papers after jointly rating 20 to achieve consensus in our ratings. Since there is no evidence based rating system for non-randomized trials, we had to develop our own. In the text, we acknowledged that the ratings were qualitative in nature and that their primary value was to explicate to the readers the bases of our evaluations.
No – as you note, the evidence is pretty inconclusive.
No
No. There really is a lack of good published evidence. One problem, however, is that the synthesis does not include operational products within agencies (i.e., white papers, special studies). In the VA, for example, OQP have conducted internal analysis of clinical quality and patient satisfaction metrics and generally found no differences between patients residing in rural and urban areas. | The task was to develop a synthesis of the existing published peer-reviewed evidence base. We did, however, examine studies conducted by OQP and AHRQ, and have commented on the findings of those reports in our discussion.
No
3. Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
Not that I am aware of.
I realize the scope of his review was on published, peer-reviewed literature but reports issued by government agencies that have undergone internal review should perhaps be considered particularly for “high level” views of disparities. The AHRQ National Health Disparities Report, as well as the VHA-published Hospital Report Cards for 2008-2010 are worth consulting. The VHA report cards include breakdown of our performance measurement system (including process and satisfaction results) by rural vs. urban residence. | As noted above, we have now examined studies conducted by OQP and AHRQ, and have commented on the findings of those reports in our discussion.
It would also be helpful to expand the scope beyond the three data sources used and include more hand searching (some was done). Inclusion of relevant dissertation research would be helpful. Assuring that negative findings are included (since there is publication bias) would strengthen the findings. | While we agree that information from well controlled studies that did not make it to publication because of negative findings would be informative, the systematic nature of the evidence based synthesis report precludes the use of non-peer reviewed literature.
None that I can think of.
The library of articles on telehealth, including telephone management. | When we began the literature review for this report, a separate report was being developed to cover the telehealth literature.
See comment above about operational products within agencies. Some of these results are available in the public domain such as Data.gov and on VA Websites. | See comments above.
This is a very complete review. | Thank you.
4. Are there any clinical performance measures, programs, quality improvement measures, patient care services, or conferences that will be directly affected by this report? If so, please provide detail. | Thank you – we will share the responses to this question with the people responsible for dissemination of the report.
No
OQP plans to use this evidence review to inform our own measurement systems and reports, and will be particularly careful in our use of risk adjustment procedures that may “adjust away” the impact of rurality. We are also working closely with the Office of Rural Health to create more robust indicators of rural health disparities and believe the partnership will be strengthened by this report.
Results should influence a) findings presented at annual HSR&D national meetings and b) programs funded by the Office of Rural Health
This report should be disseminated widely and used as the basis for creating an agenda for systematically closing gaps in both knowledge and practice. VA's various centers (e.g., VERCs and QUERI groups) can use this report to help focus their efforts and assure that their work is applicable to veterans in rural and highly rural areas.
Not that I am aware of.
This paper has the potential to significantly impact and direct future directions in rural health research and rural health clinical implementation and quality improvement efforts.
5. Please provide any recommendations on how this report can be revised to more directly address or assist implementation needs.
a. I recommend leaving out studies that you do not believe contribute. It becomes hard to pick up on the important, relevant findings when everything is presented. Several of the studies were of different provider types not urban/rural differences in health care in my opinion. I also think that more clearly weighting and emphasizing the studies that you believe really are valid and generalizable would improve this paper.; b. I think you should add a quality rating column to your evidence tables. It is hard to go back and forth. I would like to see good summary tables in the text when possible. | We have clarified study quality within the text and have added the final Confidence Score rating to our evidence tables to assist readers.
You may be able to give more specific recommendations to policy makers, such as which definition of rurality to use, as well as specific advice on how to adjust for patient mix so as not to submerge important rural/urban disparities. | It is our belief that the convention to be used in studies for the categorization of population density cannot be determined by this review and likely will vary depending on the type of study being conducted. Similarly, case mix adjustment depends on the focus of the study (e.g., whether or not to adjust for travel distance) will vary depending on the focus of the study.
It would be helpful if there were tables (similar to the ones presenting the strength of evidence) with a + or a − or a NS, indicating which studies found significant rural-urban differences in the main constructs examined. This would allow the reader to get a quick visual on how many and what proportion of studies found differences in diabetes outcomes, for example. | We have added ‘+’ and ‘-’ indicators to our tables to assist readers.
Section a beginning on page 49 seems out of place in a summary section. Perhaps it would fit better directly after page 45. | When we began this report, a separate systematic review was to be conducted on telehealth interventions. For this reason, we chose to NOT evaluate telehealth studies and to focus instead on other types of interventions. However, since that review was not conducted, we agree with reviewers that examining only non-telehealth interventions makes little sense and so we have excluded that section from the final report.
This is a very dense report with lots of information. I liked the way the authors categorized their review by both their main questions and by disease categories within those. Some specific comments/suggestions:; a. Spell out their search terms – saying standard search terms isn't enough; b. Specify that you used the VA definition in the intro when you say 40% of veterans are rural; c. Even though it's already very long, the review really does lack the whole piece on telehealth that the VA in particular uses to compensate for in-person ambulatory access deficits. At least need to explain why you left that out.; d. Since this is a VA report, it might be helpful to segregate VA and non-VA studies within each category, or at least put asterisks on VA studies to denote them. Even saying they looked at “veterans” doesn't say for sure they were looking at VA services, or even VA users.; e. In terms of interventions, I didn't see a section on that to be able to give feedback on. I assume this would be the place to include telehealth. This may call for a separate literature review to include all telehealth terms and not rely on “rural” “urban” terms to get at the articles they want.; f. The point about paucity of prospective (or even longitudinal but non-interventional) studies is really important. I think this is where HSR&D should make the point (to ORH) that improving care and access to rural veterans is not just about observing and recording what's out there, but about planning interventions and prospectively evaluating their effect on rural veteran's health and access. | We have clarified our methods and the reasons why a review of telehealth interventions were not included. The section on interventions was removed for the reasons noted above. There were an insufficient number of studies conducted within VA to separate them. However, we specifically note VA studies when they were reviewed.
Inclusion of non-published results per above comments. Because of the complexity of the issues, report should strongly recommend thoughtful “risk adjusted” analysis | Implications for risk adjustment have since been emphasized in the report.
Additional Comments:
The finding that continuity of care was reported for rural residents although there was no evidence that they were more likely to have a usual source of care seems incongruous | The distinction has now been clarified in the text.
“Among the findings were higher rates of invasive cancer related to lower rates of screening” – Please specify – did the findings really link these two? | Yes, for cervical and breast cancers as we note.
“Potential interactions of rurality and race (and/or income) should be considered.” – You might comment that this area of research (at least evaluating outcomes) is extremely prone to confounding eg. people may move to urban settings when ill/needing more health care or, people who chose rural locations might make other health care choices than those choosing an urban setting | This was noted in the discussion.
“It remains to be determined, however, whether the observed lower health quality of life among rural veterans is due to differences in disease prevalence, disparities in health care or both.” Or, different people choose different locals to live in. it is more complex than this in my opinion | We agree, and further clarified this in the text.
Regarding the literature search strategy figure, do you think there would be any value in adding more arrows to the bottom box telling what category the papers fell into? | We feel this might increase confusion.
The Institute of Medicine definition of disparity does not include variation due to differences in access (IOM, 2003). -Not sure I agree with this statement. I thought the IOM focused on all differences in utilization that were not due to differences in need and preference. I would just drop this sentence and the next | The specific reference was clarified in the text.
It might be nice to rate the relevance of the evidence to veterans. Perhaps each summary could start with the VA study or state that no VA study exists. | We specifically indicated which studies focused on veterans. Since many veterans use non-VA care and many of those who use VA split their care between VA and community providers, all studies are potentially relevant to veterans.
Mental Health section: Two studies were missed from the Journal of Rural Health that I think are important. One is a VA study. Cully JA, Jameson JP, Phillips LL, Kunik ME, Fortney JC. Use of Psychotherapy by Rural and Urban Veterans. Journal of Rural Health, 26(3): 225-233, 2010. Fortney JC, Harman JS, Xu S, Dong F. The Association between Rural Residence and the Use, Type, and Quality of Depression Care, Journal of Rural Health,26(3): 205-213, 2010. | These studies were published after our March 2010 pull date. However, given their relevance we note their findings in the discussion.
This study found higher suicidality in rural versus urban: Rost, K., M. Zhang, et al. (1998). “Rural-urban differences in depression treatment and suicidality.” Medical Care 36(7): 1098-1107. | This study, which was already included in the review, was added to the section covering suicidality.
Here are two papers showing that rurality is related to hospitalization rates for depression and schizophrenia: Fortney J, Rushton G, Wood S, Zhang l, Xu S, Dong F, Rost K. Community-Level Risk Factors for Depression Hospitalizations. Administration and Policy in Mental Health and Mental Health Services Research, 34(4): 343-352, 2007 Fortney J, Xu S, Dong F. Community-Level Correlates of Hospitalizations for Persons with Schizophrenia, Psychiatric Services, 60(6): 772-778, 2009. | We included these per your recommendation; however, the methods used were only suggestive regarding reasons for differential hospitalization rates in rural vs. urban areas.
“Moreover, while rural residents were found to receive fewer MH services than urban residents in several studies, the clinical impact of this difference was unclear.” - See this article: Fortney J. Rost K. and Zhang M. The Impact of Geographic Accessibility on the Intensity and Quality of Depression Treatment. Medical Care 37(9):884-893, 1999. | We have now included this article in our review.
Regarding CBOCs and VAMCs This study is actually the better study, as it is quasi-experimental: Fortney J, Maciejewski M, Warren J, and Burgess J. Does Improving Geographic Access to VA Primary Care Services Impact Patients' Patterns of Utilization and Costs? Inquiry, 42(1):29-42, 2005 | The relationship between CBOC placement and rurality is not uniform, which is why we did not include this interesting article in our review.
Travel Distance - There are actually lots and lots of travel distance articles which you didn't find because you were searching for rural vs urban studies You might need to either drop this or expand your search. | We agree that our search terms did not allow us to comment sufficiently on this topic
“There is some weak evidence that urban residents have a lower threshold for seeking mental health care than do rural residents” - I don't really believe this. Severity at intake is not different between rural and urban patients. | We are aware of no studies that actually asses provider availability and patient treatment attitudes and needs in urban and rural residents and then associate those differences with use of mental health services.
“As has been shown by others (Weeks, Wallace, 2008; Berke, 2009; Stern, 2010) the definition of rural that is used in a study has a significant impact on the findings and, consequently, the policy implications.” - I would also reiterate that rural is a proxy for many different things (travel time, stigma, lack of insurance, etc.), and that the rural vs urban literature does not determine what underlying factors are driving the findings. | We have clarified this in the report.
“Because many factors are correlated with rurality, adjusting for all available covariates may lead to false conclusions regarding the association of rurality and study outcomes, and provide insufficient information for the development of healthcare policy. For most research questions, a more contextual analytic approach should be used.” – Good observation! Might want to include this point in the executive summary. | Thank you for this recommendation. We have now done so.
Where possible use data / numbers (and indicate statistical significance, if appropriate) instead of phrases like, little difference, or increased rates etc. or give the page number where the specific data is found later in the document | We have tried to improve the clarity of findings in the report.
“However, all but one study found a greater frequency of unstaged cancer at the time of diagnosis in rural areas compared to urban areas.” - I think it would be good to mention the outcomes (present or absence of data) on how this finding affects mortality | No information about the implications of unstaged disease for outcomes were made in the papers reviewed. The odds of unstaged disease was not a primary focus of the studies, but was an incidental finding.
“Moreover, health care systems operate locally and identifying areas where problems are greatest would help policy makers target areas that have the most need.” - Rurality may very well be different in various parts of the country i.e. rural Alaska is different than rural Mississippi etc. | We think these differences have received very little attention.