# SUMMARY AND DISCUSSION

Substance use disorders, including alcohol use disorder (AUD), are among the most common and costly conditions among Veterans presenting for treatment in the Veterans Health Administration (VHA) system.12,13 A recent systematic review8 found moderately strong evidence that in-person, multi-contact, brief behavioral interventions decreased alcohol consumption in primary care patients who screened positive for alcohol misuse. Electronic interventions (e-interventions) for alcohol misuse have been proposed as a useful way to extend the reach of initial intervention and relapse prevention to maintain treatment gains for alcohol misuse.

We identified 26 randomized controlled trials (RCTs) involving 14,497 total participants that were relevant to our key questions (KQs). Participants were selected for these trials based on one or more alcohol consumption criteria, but only 3 studies based inclusion on an assessment of AUD. Most trials compared e-interventions with inactive controls. E-interventions were typically accessed online and consisted of one session completed without supplementary human support; personalized normative feedback (PNF) was the predominant strategy. Studies and participants were roughly equally divided between college students and other groups of adults. Adult participants were typically midlife, the majority of whom had at least some college education, with baseline alcohol consumption in excess of 14 drinks per week.

We assessed the strength of evidence (SOE) for the highest priority outcomes—alcohol consumption and alcohol-related social problems. Overall, there was low SOE that e-interventions compared with inactive controls did not decrease alcohol consumption outcomes in participants with alcohol misuse. In patients with AUD, a multicomponent smartphone application decreased the risk of relapse after residential treatment (SOE=low). In the few studies using face-to-face treatment as the comparator, e-interventions alone or in combination with face-to-face treatment were not associated with decreased alcohol use, but these studies were conducted exclusively in student populations. Interactive voice response (IVR) e-interventions may be less effective than face-to-face treatment. Table 9 details SOE ratings for the highest priority outcomes by KQ.

Table 9 Detailed SOE Ratings

Outcome | SOE Domains | | | | Effect Estimate (95% CI) | SOE
Outcome | Number of Studies (Participants)^*^ | Study Design/Risk of Bias | Consistency Directness | Precision Publication Bias | Effect Estimate (95% CI) | SOE
KQ 2: E-intervention vs control in individuals who screen positive for alcohol misuse
Alcohol consumption (weekly) | 17 (10,122) | RCT/Moderate | Inconsistent Direct | Imprecise None detected | MD -25.0 g/week (-59.3 to 9.3) Adults, n=6 studies MD -12.4 g/week (-26.6 to 1.9) Students, n=8 studies | Low Low
Met alcohol consumption limits | 6 (4932) | RCT/Low | Some inconsistency Direct | Imprecise None detected | RR 1.22 (0.79 to 1.89) Adults, n=4 studies OR 1.53 (1.09 to 2.17) Students, n=1 study | Low Low
Alcohol consumption (binge drinking) | 8 (5043) | RCT/Low | Some inconsistency Some indirectness | Precise None detected | MD 2% with binge Adults, n=2 studies MD -0.01 episodes (-1.0 to 0.9) Students, n=4 studies | Moderate Moderate
Alcohol-related social problems | 8 (5765) | RCT/Low | Some inconsistency Some indirectness | Precise None detected | No difference Adults, n=1 study SMD -0.04 (-0.22 to 0.13) Students, n=7 studies | Low Moderate
KQ 3: E-intervention vs control in individuals with AUD
Alcohol consumption (maintain abstinence) | 3 (533) | RCT/Moderate | Consistent Direct | Imprecise None detected | Increase in abstinence for adults with smartphone e-intervention: OR 1.94 (1.14 to 3.31) No difference with IVR or computerized feedback | Low Insufficient
Alcohol-related social problems | 2 (409) | RCT/Moderate | NA Direct | Imprecise None detected | No difference in adults | Low
KQ 4: E-intervention vs face-to-face counseling
Alcohol consumption^†^ | 3 (438) | RCT/Moderate | Consistent Some indirectness | Imprecise None detected | Ranged from 50 to 80 g/week higher with e-intervention Students, n=3 studies | Low
Alcohol-related social problems | 1 (210) | RCT/Moderate | NA Some indirectness | Imprecise None detected | SMD -0.16 (-0.76 to 0.43) Students, n=1 study | Insufficient
KQ 4: Combined e-intervention + face-to-face counseling vs face-to-face counseling alone
Alcohol consumption | 3 (668) | RCT/Moderate | Consistent Some indirectness | Imprecise None detected | Adults: No difference in 1 study; higher in 1 study Students: No difference in 1 study | Low Low
Alcohol-related social problems | 0 | NA | NA NA | NA NA | No studies | Insufficient

* Numbers given here are for the total number studies/participants considered in the SOE ratings. Numbers included in the summary effect estimates may vary.

† One standard drink in the U.S contains 14 grams of alcohol (eg, one 12-ounce beer that is 5% alcohol by volume).

Abbreviations: AUD=alcohol use disorder; CI=confidence interval; e-intervention=electronic intervention; g=grams; IVR=interactive voice response; KQ=key question; MD=mean difference; n=number; NA=not applicable; OR=odds ratio; RCT=randomized controlled trial; RR=risk ratio; SMD=standardized mean difference; SOE=strength of evidence

## SUMMARY OF EVIDENCE BY KEY QUESTION

### KQ 1 Characteristics of and User Support for E-Interventions

The e-interventions for alcohol misuse were typically brief, consisting of one session lasting 30 minutes or less. Intervention content was often focused on psychoeducation, PNF, and negative consequences expected from continuation of the participant's current level of alcohol consumption. Interventions including more complex psychotherapy content typically utilized a motivational interviewing approach, with relatively little cognitive-behavioral intervention beyond psychoeducation. Overall, the majority of e-interventions did not utilize supplementary human support. Even when such support was provided, it rarely included counseling beyond brief advice to reduce alcohol consumption levels. Only a single study meeting inclusion criteria used a smartphone as the delivery platform.

### KQ 2 Effects of E-Interventions Compared with Inactive Controls in Adults who Misuse Alcohol

We found low SOE that e-interventions relative to inactive controls (usual care, waitlist, or attention controls) decreased weekly alcohol consumption (n=17 studies) or increased the proportion meeting drinking limits (n=6 studies) in participants with alcohol misuse. Treatment effects varied importantly across studies, and we were unable to definitively explain this variability. Qualitative analyses suggested that studies using more intensive treatment were associated with greater reductions in alcohol consumption. This observation is consistent with a previous systematic review that found short-term effects of single-session PNF interventions were inferior to e-interventions with longer duration.27 Relative to the variability in the observed effects, the summary effects were modest, ranging from 1 to 2 fewer drinks per week, suggesting a modest long-term (≥6 months) effect of e-interventions on alcohol misuse outcomes. These estimates of treatment effect could be biased toward the null because control participants' behaviors may have been affected by assessments of alcohol misuse—similar to a placebo effect in drug studies.

While most studies provided data on the weekly volume of alcohol consumption, other important outcomes targeted in this review, such as effects on alcohol-related health and social or legal consequences, were reported infrequently. Moderately strong evidence showed no effects on binge drinking or alcohol-related social problems, but these outcomes were reported primarily in student samples. The SOE for the longer term (≥6 months) benefits of e-interventions on alcohol consumption and its associated effects on health and well-being is low. However, due to the small number of studies evaluating several of the relevant outcomes, the brevity and limited scope of the e-interventions, and the lack of supplementary human support for these interventions, further research is warranted.

### KQ 3 Effects of E-Interventions Compared with Inactive Controls in Adults at High Risk of AUD (eg, AUDIT-C ≥8) or with a Diagnosis of AUD

Three studies compared e-interventions with inactive controls or treatment as usual in participants with AUD. One study33 randomized participants to one of 2 groups utilizing computerized feedback with up to 4 phone counseling sessions lasting 30 minutes each or a control group receiving no intervention. This study is relatively novel in providing such extensive counseling, but data from the study did not provide evidence of long-term effects on alcohol outcomes. A second study evaluated a multicomponent smartphone application in patients completing residential treatment and found higher rates of abstinence and fewer risky drinking days.52 The final study60 recruited inpatients who were randomized at discharge to one of 2 groups using IVR assessments of drinking-related variables and tailored treatment modules with an option to request a counseling phone contact or a control group receiving no intervention. There was no significant effect of the e-intervention on reported alcohol outcomes. Thus, with widely varying interventions, there are conflicting findings on the efficacy of e-interventions for long-term alcohol consumption in participants with AUD. We found low SOE that a smartphone intervention decreased risk of relapse, but the evidence was insufficient for other e-interventions. There was insufficient evidence for evaluating other alcohol-related outcomes.

### KQ 4 Effects of E-Interventions Alone or Used in Combination with Face-to-Face Therapy Compared with Face-to-Face Therapy Alone in Adults who Misuse Alcohol

Six studies compared e-interventions, used either independently or in conjunction with face-to-face counseling, to treatment consisting of face-to-face counseling alone. Three of the 6 studies combined e-interventions with face-to-face treatment. Those studies utilized IVR as the e-intervention and brief motivational interviewing (BMI) as the counseling component.

In collegiate populations, BMI delivered face-to-face was generally more effective than e-interventions alone in decreasing alcohol consumption. No studies compared these interventions in non-college samples. Although the available evidence suggests that e-interventions alone are inferior to face-to-face BMI, the small number of trials and the use of college student samples result in a low SOE. In studies using combined e-intervention and face-to-face counseling, 2 studies found no difference and one study found higher reported alcohol consumption with the combined intervention relative to face-to-face counseling alone. We judged the SOE for combined IVR and BMI interviewing as low. Other types of combined e-interventions have not been researched.

## CLINICAL AND POLICY IMPLICATIONS

Though prior systematic reviews have found positive short-term effects on alcohol consumption in students, those effects have generally not been maintained at longer term follow-up.24 This is consistent with the results of our review, which examined trials reporting alcohol-related outcomes at ≥6 months and found absent to modest effects. In addition, the few available trials suggested that e-interventions might be less effective than face-to-face counseling, a finding also supported by prior reviews in student samples.24 Prior syntheses that evaluated studies in adults have found few studies. Khadjesari and colleagues26concluded that “computer-based interventions may reduce alcohol consumption compared with assessment-only,” but only 6 of the 24 studies included in this review were conducted in non-student samples, and only 2 of those reported outcomes at ≥6 months. Riper and colleagues concluded that “E-self-help interventions without professional contact are effective in curbing adult problem drinking in high-income countries.”27 However, 4 of the 9 studies assessed outcomes at ≤3 months, and 8 studies included in our review were not evaluated in the Riper review, primarily because they were published after the search date.

The presence of systematic annual screening for alcohol misuse in primary care using the Alcohol Use Disorders Identification Test for Clinicians (AUDIT-C) provides a good means of identifying patients who would be candidates for e-interventions if they decline specialty clinic treatment. However, the evidence in favor of existing e-interventions is low, suggesting that further work is needed to develop effective e-interventions for alcohol misuse. Further, it is not clear whether brief intervention for alcohol is effective for AUD specifically, as the majority of studies target alcohol misuse. This is problematic, as previous reviews of brief alcohol interventions have commented that they do not seem to be as effective in people with AUD.8,70 Limited data from adult studies suggests a possible benefit of increasing the intensity of e-interventions by extending treatment duration, adding phone counseling, or utilizing mobile applications. More intensive supplementary human support might also improve participant engagement and the effectiveness of e-interventions. More research is needed to determine whether this is effective, as there were not enough e-interventions incorporating a human support component for us to carry out quantitative analyses that resulted in reliable estimates of effect modifiers.

If effective e-interventions can be developed and tested, they have the potential to address many of the barriers to face-to-face treatment of alcohol misuse. For example, some data suggest that Veterans would prefer the convenience of e-interventions71 as opposed to negotiating the latency to treatment initiation, time investment, and travel barriers to attending clinic visits. In addition, health care providers cite barriers to addressing alcohol misuse at clinic visits that could be circumvented by utilizing e-interventions. The barriers for health care professionals include perceived inadequate training and treatment resources,72 time constraints,73 and concerns about negative effects on the doctor-patient relationship.74

There are also methods by which e-interventions could be designed to prevent relapse after the termination of intensive face-to-face counseling to achieve initial abstinence from alcohol. The continuing utilization of e-interventions could provide an accessible way for individuals to utilize treatment components originally introduced during face-to-face counseling. New programs could be tailored to a Veteran sample and could incorporate recent developments in treatment as well as be adapted for increasingly prevalent technologies such as smartphones. VHA has introduced some smartphone applications that offer assessment, basic coping tools, and referral to treatment resources. Designing e-intervention materials specifically for mobile devices could be accomplished by translating the content generated in counseling sessions for the patient to carry with them throughout the day, including high-risk situations. Clinicians and patients could also tailor e-intervention content to incorporate personalized motivations to stop drinking, avoid situations that increase the risk of relapse, and use coping strategies. The trial by Gustafson and colleagues52 incorporated these principles and demonstrated benefit in maintaining abstinence in patients completing treatment for AUD.

Many of the e-interventions we reviewed were focused on psychoeducation and PNF, with relatively few data available on e-interventions incorporating treatment components that are a standard part of psychotherapy for alcohol misuse. Studies including a broader range of treatment techniques typically reported application of motivational interviewing components. Given the central importance of relational components such as partnership and empathy in conventional face-to-face motivational interviewing, it is unclear the degree to which e-interventions actually replicate the core processes of motivational interviewing. Interventions may be enhanced by faithfully replicating core components of motivational interviewing, incorporating other proven therapies such as cognitive-behavioral techniques or pairing e-interventions with pharmacotherapy for alcohol misuse.

One recent example is a trial by Brief and colleagues75 that was ineligible for inclusion in our quantitative analyses because the final follow-up assessment was at 3 months post-randomization. However, it is relevant to this review because it was conducted with Veterans and included coping skills for the common comorbidity of alcohol misuse. The e-intervention used 8 online modules lasting approximately 20 minutes each to provide personalized feedback, facilitate decisional balance, set drinking goals, and receive feedback on progress toward goals. Veterans also received information on skills for coping with trigger situations including PTSD-related symptoms (stress, mood, and anger management) and practices to promote normal night-time sleep. Relative to waitlist, participants receiving the e-intervention significantly reduced alcohol consumption, binge drinking episodes, and alcohol-related problems. The median drinks per day decreased from 24 to 6 at 3-month follow-up. Results suggest the potential utility of e-interventions that are more intensive and broaden their strategies to address related problems that could be contributing to drinking behavior.

One expected contribution of e-interventions is the provision of low-cost clinical services to treat chronic problems such as alcohol misuse over a long period of time without utilizing a great deal of clinical resources. This efficient use of Veterans Affairs (VA) resources to improve the reach and long-term efficacy of alcohol treatment could provide valuable information to determine the value of e-interventions to the VA system. Consequently, clinical researchers could provide important contributions by including measures of cost-effectiveness in trials, especially when comparing e-interventions to traditional, clinic-based, face-to-face treatment.

The use of e-interventions for alcohol misuse will ultimately require attention to privacy and information security risks. Researchers must address these risks, eliminating them when possible and, if not possible, attending to the need to effectively communicate risks to Veterans using the technology. This includes the risk of information being intercepted during transmission to the study site, as well as breaches in the information stored at the study site and on computers and phones accessing the e-intervention.

## LIMITATIONS

Our review builds upon and extends prior reviews by following a protocol-based, transparent process that engaged relevant VA policy makers; including recently published studies; and taking an inclusive approach to electronic interventions. Another strength is the focus on sustained effects of e-interventions, prioritized as clinically important by our research team and technical expert panel. Our review has limitations as well. These include statistical assumptions in transforming data reported in many different formats into a common metric (eg, grams of alcohol per week), and judgments about when to combine multiple e-interventions tested in a single trial for meta-analyses. We also made the judgment not to conduct subgroup analyses, having specified in advance that these analyses would be conducted only if subgroups contained at least 4 studies per group. Other research teams may have made different decisions.

The literature also had important limitations. Because outcomes were self-reported, daily IVR interventions may have “trained” participants to report more alcohol consumption more accurately, biasing these studies against an intervention effect. Others have found that assessment itself has been associated with reduced alcohol consumption,8 so alcohol consumption reductions in the e-intervention groups could have been concealed by concurrent reductions in inactive control groups. The relatively low intensity of the interventions in the available literature on e-intervention for alcohol misuse limits the reliability of conclusions drawn about e-interventions as a general approach. In particular, the lack of data on the incremental efficacy of including various levels of supplementary human support prevents evaluation of potential applications of e-interventions for alcohol misuse. The small number of studies or subgroup analyses reporting on effects in participants with AUD limits interpretation for specialty clinic-based clinicians who typically treat patients with AUD specifically, as opposed to alcohol misuse generally. Other study limitations are described below.

### Publication Bias

To assess for publication bias, we searched ClinicalTrials.gov to identify completed but unpublished studies that would likely meet our eligibility criteria. Two such trials were identified from this search. The small number of trials reporting given outcomes prevented reliable quantitative evaluation of publication bias. Funnel plots were not used because analyses did not meet the minimum threshold of at least 10 studies for meaningful analysis.

### Study Quality

We assessed study quality by having 2 independent investigators provide a rating of risk of bias. Most trials were judged to be at moderate risk of bias (n=14); 5 were at low risk, and 7 were at high risk of bias. In this literature, the most common study limitations increasing risk of bias were lack of participant blinding to study condition and incomplete or perceived potential for selective reporting of outcome data.

### Heterogeneity

For effects on alcohol consumption, treatment effects varied from moderate to substantial. Variability in treatment effects were observed despite separate analyses for college samples and other adults. The variability in treatment effects on alcohol consumption limits the conclusions that can be drawn.

### Applicability of Findings to the VA Population

In VHA, Veterans are screened annually for alcohol misuse using the AUDIT-C; approximately 15% screen positive. Among those who screen positive, >80% screen positive for alcohol misuse, with <20% screening positive at a threshold (eg, AUDIT-C ≥8) suggesting probable AUD. The majority of trials in this review used similar methods to enroll participants, and exclusion criteria were relatively few. In other aspects, these trials may have limited applicability to VA. Only one trial50 was conducted in a VA sample, half the trials were conducted in college students, and over half were conducted outside the United States. In the non-college samples, midlife adults, the majority of whom were college educated, participated; this is in contrast to the predominantly older population currently served by VA. Co-existing mental illness is common with alcohol misuse, but other mental illness diagnoses were not reported in these studies, introducing uncertainty about the applicability of these findings to Veterans with alcohol misuse and coexisting depression or anxiety disorders.

## RESEARCH GAPS/FUTURE RESEARCH

Although the current state of the evidence does not strongly support long-term benefit from e-interventions for alcohol misuse, the evidence for short-term effects from low-intensity interventions and longer-term effects from higher intensity interventions suggests the potential for benefit. Table 10 identifies gaps in evidence and study designs that could address these gaps. Although it would be possible to generate an extensive list of gaps in evidence, we restricted this list to the areas judged to be highest priority, given the current state of evidence. To facilitate future literature syntheses, we encourage investigators conducting clinical trials to include these studies in trial registries.

Table 10 Highest Priority Evidence Gaps

Evidence Gap | Study Designs
Uncertainty about effects in adults with varying educational levels and co-occurring mental and physical illness | RCTs in well-described samples with analyses for interaction effects by education and other mental or physical illness
Uncertain effects in older adults | Observational studies to evaluate interest, user interface issues, and barriers to e-interventions in older adults
Uncertainty about the effects of multi-session, multi-component interventions | RCTs
Uncertainty about whether effects found in alcohol misuse generally are applicable to individuals meeting criteria for an AUD | RCTs requiring AUD for inclusion or reporting AUD as a subgroup analysis
Uncertainty about effects of robust e-interventions used in combination with face-to-face therapy. | RCTs of combined treatments that include economic outcomes
Uncertainty about the validity of self-reported outcomes for alcohol consumption | Bioverification measures, the use of collateral informants to provide independent reports of drinking behavior, or mobile monitoring that would allow frequent breath alcohol assessments in participants' naturalistic environments

Abbreviations: AUD=alcohol use disorder; RCTs=randomized controlled trials

## CONCLUSIONS

The limited evidence from trials of e-interventions compared with controls on long-term (≥6 months) alcohol outcomes in participants who screened positive for alcohol misuse suggests that effects are small or absent. The available data were even more limited for participants with AUD or comparisons of e-interventions with face-to-face treatment. Further research is needed to determine with higher confidence whether e-interventions can produce long-term benefits for alcohol-related outcomes. In particular, given the limited number and duration of intervention episodes in the studies reviewed, it is possible that these e-interventions were simply not designed to produce enduring effects on alcohol misuse. As reported in previous reviews, brief, in-person interventions can produce sustained reductions in alcohol consumption in those with hazardous drinking who do not meet criteria for AUD, which likely provides benefits at the public health level, and that could be the primary value of these low-intensity interventions. At this time, the evidence does not support substitution of e-interventions for brief, in-person treatment. Future research on e-interventions should include evaluations of more intensive or longer duration alcohol e-interventions.