# RESULTS

## LITERATURE FLOW

The flow of articles through the literature search and screening process is illustrated in Figure 1. We identified 704 unique citations from a combined search of PubMed (n=319), Embase (n=154), PsycINFO (n=14), and The Cochrane Library (n=19) and a separate search for IVR studies (n=198) conducted from January 1, 2000, through August 18, 2014. We also searched the bibliographies of seminal, exemplar studies for articles not retrieved by our search (n=18), for a total of 722 citations. After applying inclusion and exclusion criteria at the title-and-abstract level, 84 full-text articles were retrieved and screened. Of these, 53 were excluded at the full-text screening stage, leaving 31 articles (representing 26 unique trials reported in 25 articles and 6 companion papers) for data abstraction. Monahan et al45 described 2 different trials in the same publication. It was necessary to contact 12 authors for clarification of abstracted elements during the course of the data abstraction process. Eleven authors responded with the requested information.

Figure 1 Literature Flow Chart

* Search results from PubMed (319), Embase (154), PsycINFO (14), and The Cochrane Library (19), IVR search (198) and manually identified studies (18)

† Manuscript reference list includes additional references cited for background and methods.

‡ One article reported data from 2 trials that we analyzed separately.

We searched ClinicalTrials.gov (www.clinicaltrials.gov) to identify completed but unpublished studies that might meet our eligibility criteria. We found little evidence of publication bias: there were only 2 completed studies for which we could not identify a publication (NCT000658398^46^ and NCT01923246^47^).

## DESCRIPTION OF INCLUDED STUDIES

We identified 26 trials that met eligibility criteria. Eleven trials were conducted in the United States (one in a VA sample); 15 were conducted in the European Union, Australia, or Canada. The populations were divided between college students (n=12) and other groups of adults (n=14). Adult studies enrolled midlife adults, the majority of whom had some college education (median 52%, range 8% to 83%). Across all studies, men and women were well-represented. Twenty-three trials recruited subjects who misused alcohol but did not meet criteria for AUD. Only 3 trials specifically recruited subjects who were at high risk of or had been diagnosed with AUD, but in many of the adult studies the mean weekly alcohol consumption exceeded 14 U.S. standard drinks per week. Study exclusion criteria were limited: 4 trials specifically excluded those in alcohol treatment, 3 excluded those with psychosis, and 2 excluded those with severe or terminal medical illness. Most trials were judged to be at moderate risk of bias (n=14); 5 were at low risk, and 7 were assessed as being at high risk of bias. Twenty-three trials compared an e-intervention with an inactive control, while 3 trials compared IVR (e-intervention via telephone lines) with inactive or active controls. Six studies compared e-interventions or IVR to a face-to-face control condition. A single trial used a mobile device as the delivery platform; none used the Health Buddy™ appliance. The most commonly reported outcomes were the characteristics of the interventions and their effects on alcohol consumption, reductions in consumption to meet drinking limits, binge drinking, and the social and legal consequences of drinking.

## KEY QUESTION 1 For e-interventions targeting adults who misuse alcohol or who have a diagnosis of AUD, what level, type, and modality of user support is provided (eg, daily telephone calls, weekly email correspondence), by whom (eg, professional counselor, technical support staff), and in what clinical context (adjunct to therapy or primary intervention)?

### Key Points

- The majority of interventions (n=14) did not utilize supplementary human support and were delivered online or at a desktop computer. A single study utilized a mobile device.
- Most interventions were a single session, designed to moderate alcohol consumption in individuals who screened positive on an alcohol questionnaire (eg. Alcohol Use Disorders Identification Test [AUDIT] or AUDIT for Clinicians [AUDIT-C]).
- The main components of the e-interventions were personalized normative feedback (PNF) and psychoeducation or alcohol-specific education including the negative consequences of drinking.
- When supplementary human support was utilized (n=12), it was limited, consisting only of technical support from a research assistant in half the cases. In other cases, it was often given in combination with IVR or combined with telephone or face-to-face treatment in subjects at high risk of or with AUD.

### General Description

We included 26 RCTs, described in 25 publications;33-36,45,48-67 the paper by Monahan and colleagues45 reported results from 2 separate trials. All 26 trials were conducted in adults 18 years of age or older, but 46% were conducted specifically in college students. The included RCTs evaluated 21 unique e-interventions—IVR (3 trials) or computer-based programs (23 trials). A single trial used a mobile device as the delivery platform;52 none used the Health Buddy™ appliance. Seventeen of the interventions used commercially available programs; however, 11 of these were each evaluated in a single study. Three programs were evaluated in 2 studies each—Electronic Check-Up to Go (e-CHUG), Alcohol 101, and Brief Alcohol Screening and Intervention for College Students (BASICS)—and these were all used in student studies. Study characteristics are described in greater details in Appendix E. Detailed descriptions of the e-interventions evaluated are provided in Appendix F. A summary of the adult versus student studies is given in Table 3.

Table 3 Characteristics of E-Interventions (KQ 1)

Characteristic | Adult Studies (n=14) | Student Studies (n=12)
Level of support:
1 (minimal) | 6 | 8
2 (low) | 4 | 4
3 (moderate or high) | 4 | 0
Number of sessions:
1 | 6 | 8
>1 | 5 (3=daily IVR) | 4 (2–5 sessions)
NR | 3 | 0
Session duration:
Median (range) | 10 (10-90) minutes | 30 (5-50) minutes
NR | 7 | 0
NA (IVR) | 3 | 0
Intervention name:
IVR | 3 | 0
Not named | 3 | 3
Alcohol 101 | 0 | 2
e-CHUG | 0 | 2
BASICS | 0 | 2
Program used only once^*^ | 8 | 3
Delivery mode:
Accessed via the Web | 8 | 8
Software on laptop or desktop | 1 | 4
Mobile device | 1 | 0
IVR | 3 | 0
NR | 1 | 0
Delivery location:
Off-site (home, IVR, etc) | 5 | 2
On-site (clinic, classroom, etc) | 3 | 5
NR | 6 | 5
Content of e-intervention:
Brief intervention | 10 | 8
PNF^†^ | GS: 6; non-GS: 1; NR: 1 | GS: 7; non-GS: 2
Psychoeducation | 8 | 8
Alcohol-specific | 3 of 8 | 4 of 8
Goal-setting | 7 | 1
Negative consequences | 5 | 4
Skills training | 2 | 1
Self-monitoring | 4 | 0
Tailored feedback | 2 | 1
Relapse prevention | 2 | 0
Other techniques (used once)^‡^ | 9 | 3

* Programs used only once: in adult trials: FRAMES, eScreen.se, www.drinktest.nl, Down Your Drink, Check your Drinking, minderdrinken.nl; in student trials: THRIVE, What do You Drink, College Drinkers Check-up

† For adults, the comparison group was usually a national population (n=3) or age-matched adults (n=3); for students, the comparison group was usually student peers (n=7).

‡ Other treatment techniques used: for adults: CBT, computer monitoring, email, GPS, taking responsibility, text messaging, values clarification; for students: homework, decisional balance exercise,

Abbreviations: BASICS=Brief Alcohol Screening and Intervention for College Students; CBT=cognitive-behavioral therapy; e-CHUG=Electronic Check-Up to Go; E-Interventions=electronic interventions; FRAMES=feedback, responsibility, advice, menu of options, empathy, self-efficacy; GPS=global positioning system; GS=gender-specific; IVR=interactive voice response; KQ=key question; NA=not applicable; NR=not reported; PNF=personalized normative feedback; THRIVE=Tertiary Health Research Intervention Via Email

In terms of the level of supplementary human support provided, we classified the e-interventions evaluated in the included studies as follows:

- Level 1 (minimal, n=14): No support; e-intervention only
- Level 2 (low, n=8): Some support; e-intervention supplemented by non-counseling meetings with study staff
- Level 3 (moderate or high, n=4): Therapeutic support; e-intervention supplemented by counseling from trained staff

### Level of Support

Over half of the e-interventions (n=14) were classified as level 1 support, which did not provide any supplementary human support, technical or therapeutic.35,36,45,50,51,53,57,59,61,64-66,68 Eight of these were collegiate studies, and the remainder (n=6) were conducted in other adult groups. All of these studies used computerized PNF as the major component of the intervention.

Four adult49,52,62,63 and 4 student34,48,56,58 studies were classified as level 2 support. This usually consisted of technical support from a research assistant, so that human contact was made, but no therapy was given. Among the adult studies, Riper et al63 used a weekly, moderated peer-support group, and Gustafson et al52 used both a peer “bulletin board” and email contact with a therapist over the smartphone application. In the other 2 trials,49,62 interaction with study staff was limited to screening questions and technical aid with the computer program. Among the student studies, one48 had an in-person assessment in both the active and control conditions in addition to technical help from the staff in the e-intervention arm. In the other 3 level 2 student studies, the only supplementary human support was technical aid from the research assistant about navigating the program.

All level 3 support studies (n=4) were conducted in non-collegiate adults.33,54,55,60 Three of these 4 studies54,55,60 were IVR trials. IVR is a technology that allows a computer to interact with humans through the use of voice and signaling over analog telephone lines. All of the IVR studies were 3-arm studies with one control arm and 2 active arms. In the first,55 the intervention started with a brief intervention with the participant's primary care provider. Afterwards, participants were randomized to control, IVR, or IVR plus PNF. Participants in IVR groups were instructed to phone in to an interactive program on a daily basis and report their alcohol consumption over the previous 24 hours. Those in the PNF group received monthly PNF from their primary care provider about their consumption in the mail. The second IVR study54 started with a motivational interview with a counselor who had either a BA or MA in psychology, supervised by a PhD in psychology, which was followed by IVR in one of the active arms. Both active arms received 2 brief (15-minute) follow-up sessions. The third IVR study60 randomized subjects to IVR only or IVR plus follow-up phone calls with the study coordinator, whose credentials were not specified, for help or guidance in relation to the intervention. The one non-IVR level 3 study33 also included 3 arms and provided a computerized “expert system intervention” (about which very little information was given) to both active arms, then randomized subjects either to counseling sessions via phone with “trained psychologists” at all follow-up assessment points (full care intervention) or only if needed (stepped care intervention). Whether the extra sessions were needed was determined by the answers to the follow-up questionnaires.

### Intervention Intensity: Number of Planned Sessions and Mean Duration of Planned Sessions

Most e-interventions (n=14) consisted of one planned session with the computer program33,36,45,49-51,53,56,58,59,61,62,66 and offered no further support beyond technical aid. In 5 of these 14 studies, the session lasted 10-20 minutes.49-51,58,66 Four studies36,45,56 had slightly more intensive e-interventions that required 30-40 minutes to complete. One study's initial session took 90 minutes to complete.62 Four studies33,53,59,61 did not report the length of the e-intervention, but one of these33 was a level 3 support study in which, although there was an initial computer session, the bulk of the treatment focused on tailored, therapeutic feedback over the phone in up to 4 scheduled phone calls that lasted 30-40 minutes each.

Five studies offered 2 to 5 sessions with the e-intervention;34,35,48,57,64; 3 studies52,65,67 offered subjects unlimited access to the program; one was delivered via a mobile phone application.52 Sinadinovic et al65 reported in response to a query that the average number of sessions was 2.66 (4.31) in the 69.3% of intervention participants who accessed the site at all. Of studies with multiple, but limited numbers of sessions, Kypri et al offered 2 short, 5- to 10- minute sessions—the initial motivational interview and a short “booster session” 1 month later—in one study57 and repeated the 10 minute e-intervention at the 1- and 6-month follow-up in another study.34 Schulz et al64 provided 3 sessions (length not reported) with the computer program at 3-month intervals. Neighbors et al35 supplied 2 to 5 computer sessions of 50 minutes each, the number and timing of which was dependent on previous adherence. Barnett et al48 required a 45-minute session with a 25-minute “booster” session 1 month later to mimic the in-person therapy control.

The other 4 eligible studies included more supplementary human support. Riper and colleagues63 used a weekly moderated peer support group accessed via the web for 6 weeks after the initial computerized assessment. The length of the group sessions was not reported. The remaining 3 studies were the IVR studies54,55,60 that included a daily brief check-in call to the program for 2, 3, or 6 months. These check-in calls, averaging 3 to 5 minutes each over 60 to 180 days, totaled 3 to 9 hours of support time. In addition to the IVR time, the IVR studies had either brief initial sessions (<15 minutes) and/or follow-up sessions (40 to 120 minutes).

One study63 did not report the number or duration of sessions, and the author did not respond to a query for this information.

### Delivery Mode and Delivery Location: Online, Desktop, IVR, and On- or Off-Site

Most programs were commercially available (n=17) and accessed online (n=16). The other delivery modes were desktop- or CD-ROM-based programs (n=5), mobile phone application (n=1), or IVR (n=3). Web-delivered interventions were sometimes accessed from dedicated computers in healthcare49 or research settings, but more often the location was not specified. Desktop-delivered interventions were typically located in a healthcare setting50,56,62 or research lab.45 Security features for the programs were not often reported (n=18). In the 3 IVR studies,54,55,60 the device was linked to the participant's home phone.

### E-Intervention Content: Theoretical Basis and Most Common Features

A conceptual framework for the program was reported for 16 of the e-interventions. In most cases (n=13), the e-intervention drew upon principles from motivational interviewing. Cognitive-behavioral therapy (n=4) or the Transtheoretical Model of Behavior Change (n=2) were occasionally used alone or with motivational interviewing.

The most commonly employed strategies used in the e-interventions are summarized by adult and college samples in Figure 2. Overall, PNF was the most common intervention strategy (n=16). PNF consists of a summary of the individual's alcohol intake compared to intake among the subject's peer group. The comparison group was usually gender-specific. In adult studies, they were often age-matched (n=4) or described as local or national population samples (n=3). In student studies, they were described as “student peers.” After PNF, the treatment techniques used most often were goal-setting, psychoeducation or alcohol-specific education, and information about the negative consequences of alcohol misuse. Other strategies that were used infrequently included: 1) assessment of attitudes, self-efficacy, and motivation to change; 2) potential strategies to implement change such as decisional balance exercises; 3) relapse prevention strategies; and 4) links to other sources of information. The one mobile application study52 used techniques specific to this platform— global positioning system (GPS) and texting.

Figure 2 Strategies Used in E-Interventions

Abbreviations: A-S=alcohol specific; E-Interventions=electronic interventions; PNF=personalized normative feedback

As described previously, level 1 e-interventions typically consisted of a single session that delivered PNF via computerized feedback or printout. To further illustrate level 2 and 3 interventions, we describe studies in general terms in Table 4.

Table 4 Examples of Level 2 and Level 3 Interventions (KQ 1)

[underlined: Level 2]: These 8 studies utilized multiple strategies beyond PNF such as the negative consequences and risks associated with alcohol intake, goal-setting, decision-making (including a decisional balance exercise in one case), measurement of motivation to change, correcting misperceptions, and skills training. In 3 cases, subjects completed an assessment that took 30 to 90 minutes.48,56,62 Five utilized an in-person appointment with a research assistant to conduct parts of the baseline assessment, which is a larger investment on both the part of the subject and the research team.34,49,56,58,62 Another example of a level 2 intervention used a web-moderated peer group that promoted self-monitoring, skills training, and goal-setting.63 Finally, a level 2 intervention delivered via mobile phone offered email correspondence with a therapist, an e-bulletin board for posting messages with peers, text-messaging, and a GPS.52
[underlined: Level 3]: One study33 used a computer psychoeducation program coupled with a brief intervention delivered by a trained psychologist, followed by 30- to 40-minute phone sessions with the psychologist at 1-, 3-, and 6-month follow-ups. Other level 3 studies54,55,60 consisted of 1 to 4 face-to-face (n=2) or telephone-delivered (n=1) therapy sessions lasting <30 minutes, combined with daily IVR for 2, 3, or 6 months. In the IVR interventions, therapy was delivered by personnel from various disciplines (study coordinator; MD; BA- or MA-level trainee supervised by a PhD-level psychologist).54,55,60

Abbreviations: GPS=global positioning system; KQ=key question; IVR=interactive voice response; PNF=personalized normative feedback

### Summary of Findings

Of 26 studies relevant to KQ 1, only 12 relied on any type of supplementary human support, and only 4 of these included support of a therapeutic nature. This could reflect the fact much of the research to date seems to examine whether a one-time intervention providing data generated from a computer program that compares an individual's alcohol consumption to the peer group norm (PNF) could moderate alcohol consumption in individuals with alcohol misuse. In addition to PNF, goal-setting and psychoeducation/alcohol-specific education including the negative effects and consequences of drinking were the most commonly reported strategies. Although many e-interventions for alcohol misuse are available, few have been evaluated in more than a single study. Most are accessible on the web, but whether or not a user name and password is required is usually not reported. The content of these computer programs varies widely, from one 10-minute session to an unlimited number of sessions that may take up to 45 minutes each to complete. Generally, interventions designed for college students were much less complex, having fewer, shorter sessions and using a more limited number of strategies. Studies in other groups of adults were more intense, containing the studies that used therapeutic support ranging from 1.5 to 5 hours and the studies that targeted subjects with more severe drinking problems.

## KEY QUESTION 2 For adults who misuse alcohol but do not meet diagnostic criteria for AUD, what are the effects of e-interventions compared with inactive controls?

### Key Points

- E-interventions identified were not intensive, typically providing one brief intervention. Existing e-interventions might not have been designed to be robust enough to produce long-term effects (≥6 months).
- Included studies generally provided data on alcohol consumption outcomes, but there were limited data on functional outcomes and quality of life.
- The available data suggest that long-term effects of e-interventions on alcohol outcomes are modest or absent.

We identified 22 studies involving 13,929 participants that met eligibility criteria for KQ 2.^33-36,45,49-51,53-59,61-67^ Study characteristics are summarized in Table 5; detailed study characteristics are presented in Appendix E. Because one of the studies had 2 e-interventions and one inactive control, allowing 2 comparisons in the same study,54 there were a total of 23 comparisons between e-interventions and inactive controls. Twelve studies were conducted in adult samples.33,49-51,53-55,62-65,67 Of these, 4 were judged to be at low risk of bias, 6 moderate risk, and 2 high risk. Another 10 studies were conducted in student samples.34-36,45,56-59,61,66 Of these, 3 were assessed as being at low risk of bias, 6 moderate risk, and one high risk. Across all studies, there were no differences in baseline alcohol consumption between intervention and control arms (MD 0.32 g/week; 95% confidence interval [CI], -2.87 to 3.50). In this literature, the most common study limitations increasing risk of bias were lack of participant blinding to study condition (demand characteristics) and incomplete or perceived potential for selective reporting of outcome data.

Table 5 Characteristics of E-Interventions (KQ 2)

Characteristic | Adult Studies (n=12; 7141 Participants) | Student Studies (n=10; 6788 Participants)
Delivery location/setting:
Clinic/emergency room: | 2 | 0
College health services | 0 | 2
College classroom | 0 | 1
Research lab | 0 | 1
Home | 0 | 2
NR | 10 | 4
Intervention name:
escreen | 1 | 0
Drinktest | 1 | 0
Down Your Drink | 1 | 0
Check Your Drinking | 1 | 0
Minderdrinken | 1 | 0
Alcohol-Everything within limits | 1 | 1
Alcohol 101 | 0 | 1
e-CHUG | 0 | 2
BASICS | 0 | 2
THRIVE | 0 | 1
What Do You Drink | 0 | 1
College Drinker's | 0 | 1
Not named | 6 | 3
Delivery mode:
IVR | 2 | 0
Accessed online | 8 | 8
Accessed on desktop computer | 1 | 2
NR | 1 | 0
Number of sessions:
1 | 6 | 8
>1 | 1 | 2
NR | 2 | 0
IVR | 2 | 0
Unlimited/unstructured | 1 | 0
Comparator:
Waitlist | 4 | 5
Attention/information control | 6 | 3
Treatment as usual | 2 | 1
Face-to-face | 0 | 1
Outcomes:
Alcohol consumption | 8 | 8
HRQOL | 2 | 0
Social/legal effects | 1 | 8
Risk of bias:
Low | 4 | 3
Moderate | 6 | 6
High | 2 | 1

Abbreviations: BASICS=Brief Alcohol Screening and Intervention for College Students; e-CHUG=Electronic Check-Up to Go; HRQOL=health-related quality of life; IVR=interactive voice response; KQ=key question; NR=not reported; THRIVE=Tertiary Health Research Intervention Via Email

### Results from Studies of Adults

Of the 12 studies conducted in adult samples, 10 provided mean age (range 32.5 to 59.3 years, median 41.1 years). The proportion of females ranged from 0 to 57%, with a median of 41%. Race or ethnicity was reported in only 2 studies. Few data were available on education, though the 7 studies reporting enough data to determine whether participants attended college had a range of 34% to 82% of participants who had attended at least some college. Data on the location of the e-interventions were lacking. Similarly, many studies did not report the name of the e-intervention programs. Of the programs reported in studies reviewed, no specific program was used by more than one study. Most e-interventions were one-session treatments that were accessed online. Half of the studies (n=6) utilized comparison conditions that provided some information or attention as a control, while the other half used waitlist or treatment as usual as comparisons. While 8 studies reported some type of alcohol consumption outcome (grams/week, binge drinking episodes, or meeting alcohol limit guidelines), only 2 studies reported HRQOL, and only one study reported on the social/legal consequences of drinking. We categorized the level of supplementary human support provided as follows: 6 studies had level 1 (minimal) support, 3 studies had level 2 (low) support, and 3 studies had level 3 (moderate or high) support.

To aggregate alcohol consumption across studies, we converted all outcomes to grams (g) of alcohol consumed per week. This generally involved converting standard drinks (U.S., European Union, or Australia) to g/drink, multiplying times the standard drinks/unit time, and then adjusting for unit of time if not given as 1 week. The National Institute on Alcohol Abuse and Alcoholism (NIAAA) defines a U.S. standard drink as a drink that contains 14 g of alcohol, which is often the amount found in a 12-ounce beer, 8 to 9 ounces of malt liquor, 5 ounces of table wine, or 1.5 ounces of hard liquor. The mean baseline alcohol consumption in studies enrolling adult samples ranged from 129 to 436 g/week (median=292 g/wk).

#### Alcohol Consumption

Figure 3 shows a forest plot of mean differences (MDs) for the 6 studies conducted with adults that had sufficient data at 6-month follow-up assessment to analyze alcohol consumption.50,51,53,62-64 In these studies, e-interventions were associated with a small, statistically insignificant reduction in alcohol consumption (MD -25.0 g/week; 95% CI, -59.3 to 9.3). Treatment effects varied moderately (Q=11.0; p=0.051; I^2^=55%). Qualitative analyses suggested that studies using more intensive treatment were associated with greater reductions in alcohol consumption. For example, the trial by Riper and colleagues63 offered access to a moderated peer-to-peer forum, and participants received the recommendation to remain engaged with the e-intervention for 6 weeks. Reductions in alcohol consumption were large. Similarly, Bischof and colleagues33 observed decreased alcohol consumption in adults at 12-month follow-up in a relatively intensive e-intervention that was combined with 4 phone counseling sessions. A sensitivity analysis that removed the 2 studies at high risk of bias found a small, statistically significant reduction in alcohol consumption (MD -14.7 g/week; 95% CI, -26.4 to -3.0), with little variability across studies (I^2^=0.0%).

Figure 3 Alcohol Consumption at 6 Months in Studies of Adults*

* Hansen 2012 and Schulz 2013: Means and SDs were not available, as only mean difference and CI were given.

Abbreviations: CI=confidence interval; N=number of participants; NR=not reported; SD=standard deviation

Five studies reported sufficient data to analyze 12-month follow-up assessments of alcohol consumption;33,51,53,62,67 3 of the studies were also analyzed at the 6-month time point.51,53,62 Figure 4 shows a forest plot for these studies. E-interventions were associated with a very small, statistically insignificant reduction in alcohol consumption at 12 months (MD -8.6 g/week; 95% CI, -53.7 to 36.5), with high heterogeneity in treatment effects (Q=14.8; p=0.005; I^2^=73%). A sensitivity analysis that removed the one study at high risk of bias was consistent with the primary analysis (MD -5.5 g/week; 95% CI, -79.0 to 68.1; I^2^=79.1%).

Figure 4 Alcohol Consumption at 12 Months in Studies of Adults

Abbreviations: CI=confidence interval; N=number of participants; SD=standard deviation

An additional study with relevance to this question was not included in meta-analyses due to the unique characteristics of its intervention and study sample, namely, face-to-face motivational interviewing plus IVR in individuals with HIV.54 In this study, a brief motivational interviewing (BMI) intervention was paired with a daily IVR system for tracking drinking behavior. Another arm of the study employed BMI only and is described under KQ 4. Relative to inactive control, the BMI plus IVR arm resulted in similar amounts of alcohol consumption at 6- and 12-month follow-up assessments.

#### Alcohol Reduction to Meet Drinking Limit Guidelines

The operational definition of drinking limit guidelines varied across studies. Studies typically defined limits by a weekly total of standard drinks (eg, <20).49,63 However, one study62 combined the weekly limit with a daily limit (≤5 drinks for men, ≤3 for women), whereby exceeding either the weekly or the daily limit would count as not meeting the guideline. The studies varied considerably in the proportion of participants meeting drinking limit guidelines at the 6-month follow-up. The 4 studies with data on this outcome reported 17%, 23%, 46%, and 78% meeting drinking limit guidelines in the e-treatment groups at 6 months.

Figure 5 shows a forest plot of risk ratios (RRs) for the 4 studies conducted in adults that had sufficient data at 6-month follow-up assessment to analyze the proportion of participants meeting drinking limit guidelines.49,62-64 In these studies, e-interventions were associated with a small, statistically insignificant increase in the risk of meeting guidelines (RR 1.22; 95% CI, 0.79 to 1.89). There was low to moderate heterogeneity in effect sizes (Q=6.5; p=0.088; I^2^=54%).

Figure 5 Alcohol Reduction to Meet Drinking Limit Guidelines at 6 Months in Studies of Adults*

* Schulz 2013 did not report event rates. Intervention effects are based on adjusted estimates reported from a logistic regression model.

Abbreviations: CI=confidence interval; N=number of participants; NR=not reported; SD=standard deviation

There were no studies with sufficient data to analyze 12-month follow-up assessments of meeting drinking limit guidelines.

An additional study targeted alcohol misuse with comorbid illicit drug use.65 This study enrolled participants online and provided a brief online intervention where participants could monitor drinking and get PNF with motivational interviewing-based recommendations. This was compared to an assessment-only condition. Drinking limits in this study were defined as AUDIT <8. At 6-month follow-up, the 2 groups had similar proportions of participants with AUDIT <8.

#### Binge Drinking

Two studies in adults reported the effects of e-treatment on binge drinking.50,53 Both trials reported 6-month data, but no 12-month data. Due to the limited number of trials, we did not conduct meta-analysis. One study enrolled military Veterans with alcohol misuse and compared treatment as usual in a primary care setting to treatment as usual plus a brief online alcohol intervention.50 Binge drinking was defined as ≥5 drinks on one occasion for men, and ≥4 drinks on one occasion for women in the past 30 days. At the 6-month follow-up, participants in the brief intervention condition had rates of binge drinking (23%) similar to those in the treatment-as-usual condition (25%). The other study reporting binge drinking outcomes in adults compared an online PNF intervention to a no-intervention control group.53 Binge drinking was defined as drinking ≥5 drinks on one occasion. At the 6-month follow-up, the binge drinking rate in the online PNF condition (47%) was similar to that of the non-intervention control condition (45%).

#### Consequences of Drinking—Social Problems

One trial, conducted in Veterans, reported intervention effects on the negative social consequences of drinking at 6-month follow-up.50 This study is also described immediately above, under “Binge Drinking.” This study measured negative social consequences of drinking with the Short Inventory of Problems, a 15-item measure on which higher scores indicate more social problems. In this study, the brief online alcohol intervention had a mean score on the self-report measure of social problems (mean 5.9, SD 10.2) that was similar to that observed in the treatment-as-usual-only group (mean 6.5, SD 9.3). No 12-month data were available.

#### Other Outcomes

In addition to the outcomes described above, we examined trials for analyses of HRQOL, alcohol-related health problems, medical utilization, and adverse effects from treatment. No trials with adults reported these outcomes with sufficient data to analyze.

### Results from Studies of College Students

Ten trials were conducted in college student samples.34-36,45,56-59,61,66 Due to theorized potential differences in sample characteristics and responsiveness to treatments, we analyzed these samples separately from the adult samples. Of the 10 trials conducted in college student samples, 8 provided mean age (median of means 19.9 years, range 18.2 to 20.9 years). The proportion of females ranged from 38% to 64%, with a median of 55%. In the 4 trials reporting race/ethnicity, the proportion of participants of non-Caucasian race/ethnicity ranged from 15% to 43%, with a median of 28%. The location of the e-interventions varied considerably, as the 6 studies reporting location included college health services, college classrooms, research labs, and home-based e-interventions. The programs used also varied, and no one program was used in more than 2 studies. E-interventions were primarily delivered online (n=8 studies). Treatment was not intensive, as the modal number of e-intervention sessions was 1 (n=8 studies). Half of the studies used waitlist comparison groups, but more active comparison groups were included, as 3 studies used attention/information comparisons, and one used face-to-face therapy as a comparison. A total of 9 studies provided data on alcohol consumption (either g/week, binge drinking episodes, or meeting alcohol limit guidelines). Eight studies provided data on negative social and/or legal consequences of drinking. No data on HRQOL were provided. Regarding the level of supplementary human support provided, 7 trials had minimal support, and 3 trials had low support. Of the 8 trials that provided baseline alcohol consumption data, baseline means were lower than in adult studies, ranging from 85 g/week to 291 g/week (median 183 g/week).

#### Alcohol Consumption

Figure 6 shows a forest plot of MDs for the 8 studies conducted in college students that had sufficient data at 6-month follow-up assessment to analyze alcohol consumption.34-36,45,57,58,61,66 In these studies, e-interventions were associated with a small, statistically insignificant reduction in alcohol consumption (MD -12.4 g/week; 95% CI, -26.6 to 1.9). There was moderate heterogeneity in treatment effects (Q=11.8; p=0.11; I^2^=41%).

Figure 6 Alcohol Consumption at 6 Months in Studies of College Students

Abbreviations: CI=confidence interval; N=number of participants; SD=standard deviation

There were also 3 studies with sufficient data to analyze 12-month follow-up assessments of alcohol consumption.34,35,56 A forest plot for these studies is shown in Figure 7. In these studies, e-interventions were associated with a small, statistically insignificant reduction in alcohol consumption. (MD -22.2 g/week; 95% CI, -96.6 to 52.3). There was substantial heterogeneity in treatment effects (Q=7.5; p=0.024; I^2^=73%).

Figure 7 Alcohol Consumption at 12 Months in Studies of College Students

Abbreviations: CI=confidence interval; N=number of participants; SD=standard deviation

#### Alcohol Reduction to Meet Drinking Limits

One study with college students had data on 6-month outcomes for meeting drinking limit guidelines.57 In this study, drinking guidelines were defined as a limit of 14 drinks per week for women and 28 drinks per week for men. The e-intervention consisted of psychoeducation about negative consequences of current alcohol consumption level, including health, financial, and motor vehicle accident risks. In addition, the e-intervention provided normative comparisons and information on treatment resources. Relative to an assessment-only comparison group, the e-intervention resulted in an elevated probability of meeting drinking limits at 6 months (OR 1.53; 95% CI, 1.09 to 2.17).

#### Binge Drinking

Figure 8 shows a forest plot of MDs for the 4 trials conducted with college students that had sufficient data at 6-month follow-up assessment to analyze effects of e-interventions on binge drinking episodes.34,35,45,58 In these studies, e-interventions were associated with a very small, statistically insignificant reduction in binge drinking (MD -0.1 episodes; 95% CI, -1.0 to 0.9), with low to moderate evidence of heterogeneity in effect sizes (Q=5.5; p=0.14; I^2^=46%).

Figure 8 Episodes of Binge Drinking at 6 Months in Studies of College Students

Abbreviations: CI=confidence interval; N=number of participants; SD=standard deviation

There were no trials with sufficient data to analyze 12-month follow-up assessments of binge drinking episodes.

Two additional trials reported the proportion of subjects with binge drinking, but these outcomes could not be combined with the mean episodes of binge drinking and thus these studies were excluded from the meta-analysis.57,66 One study compared a brief online e-intervention to a no-intervention comparison group.66 At the 6-month follow-up, the proportion of participants reporting binge drinking in the e-intervention group (68%) was similar to that in the control group (66%). Another trial compared a brief online e-intervention to an informational leaflet intervention.57 Binge drinking was defined as >120 g for males and >80 g for females during one episode in the last 2 weeks. The median number of binge drinking episodes was the same for both groups (median=1). These findings of no intervention effect on episodes of binge drinking are consistent with the finding of no effect on mean number of binge drinking episodes for the studies included in the meta-analysis.

#### Consequences of Drinking—Social Problems

Figure 9 shows a forest plot of SMDs for the 7 trials conducted in college students that had sufficient data at 6-month follow-up assessment to analyze the effects of e-interventions on negative social consequences of drinking.34-36,57-59,61 In these trials, e-interventions were associated with a very small, statistically insignificant reduction in the negative social consequences of drinking (SMD -0.04; 95% CI, -0.22 to 0.13), with moderate heterogeneity in treatment effects (Q=14.1; p=0.029; I^2^=57%).

Figure 9 Negative Social Consequences of Drinking at 6 Months in Studies of College Students

Abbreviations: CI=confidence interval; N=number of participants; SD=standard deviation; SMD=standardized mean difference

Figure 10 shows a forest plot of SMDs for the 4 trials with sufficient data at 12-month follow-up for assessment of negative social consequences of drinking.34,35,56,59 Similar to results observed in the 6-month data, e-interventions were associated with a very small, statistically insignificant reduction in negative social consequences of drinking at 12-month follow-up (SMD -0.03; 95% CI, -0.59 to 0.54); there was substantial heterogeneity in treatment effects (Q=26.4; p<0.001; I^2^=89%). A sensitivity analysis that removed the one study at high risk of bias was consistent with the primary analysis (MD -0.12 g/week; 95% CI, -0.98 to 0.74; I^2^=90.9%).

Figure 10 Negative Social Consequences of Drinking at 12 Months in Studies of College Students*

* Hester 2012 did not report mean and SD. The estimate of treatment effect was derived from other statistics.

Abbreviations: CI=confidence interval; N=number of participants; SD=standard deviation; SMD=standardized mean difference

#### Other Outcomes

No trials in college students reported HRQOL, alcohol-related health problems, medical utilization, or adverse effects from treatment with sufficient data to analyze.

### Summary of Findings

We reviewed a total of 22 studies that compared e-interventions with inactive controls in participants with varying degrees of alcohol misuse. Most interventions were accessed online, used a single session, and had minimal to low levels of supplementary human support. While most studies provided data on alcohol consumption outcomes, other important outcomes were reported infrequently. Treatment effects on weekly alcohol consumption were relatively small and statistically insignificant, and varied importantly across trials. Fewer studies provided data on meeting drinking limit guidelines at the end of the study, reducing binge-drinking episodes, and decreasing social problems related to alcohol. Moderately strong evidence showed no effects on binge drinking or alcohol-related social problems, but these outcomes were reported primarily in student samples. The strength of the current evidence for the longer-term (≥6 months) benefits of e-interventions on alcohol consumption and its associated effects on health and well-being is low.

### Quality of Evidence for KQ 2

Of the 22 trials relevant to this question, 7 were judged to be at low risk of bias, 12 at moderate risk of bias, and 3 at high risk of bias (Appendix C). We used the Grading of Recommendations Assessment, Development and Evaluation (GRADE) approach to rate the overall strength of evidence (SOE) for outcomes that addressed alcohol consumption and social problems related to alcohol use. For 2 of the alcohol consumption outcomes (weekly consumption and meeting alcohol limits), we judged the SOE as low. The SOE was downgraded for inconsistent and imprecise treatment effects and, for the weekly consumption outcome, moderate risk of bias. Moderately strong evidence showed no effects on binge drinking or alcohol-related social problems, but these outcomes were reported primarily in student samples. These outcomes were downgraded for some important inconsistency in treatment effects and indirectness, since most of the studies involved student samples with lower baseline alcohol consumption than the adult samples.

## KEY QUESTION 3 For adults at high risk of AUD (eg, audit-C ≥8), or who have a diagnosis of AUD, what are the effects of e-interventions compared with inactive controls?

### Key Points

- Only 3 studies compared e-interventions with no-intervention controls in participants with AUD (n=533).
- In a single trial, a multi-component smartphone program used to support recovery following residential treatment increased abstinence (OR 1.94; 95% CI, 1.14 to 3.31) and decreased risky drinking days at 12-month follow-up (SOE=low).
- A computerized feedback system coupled with telephonic counseling in participants recruited from primary care did not reduce alcohol consumption. An IVR system used for participants discharged from residential treatment did not decrease the risk of relapse (SOE=insufficient).

### Study Characteristics and Treatment Effects

We identified 3 trials (Table 6) involving 533 participants that met inclusion criteria for KQ 3.^33,52,60^ All studies were conducted in adult, non-student samples and were judged to be at moderate33,52 or high60 risk of bias (Appendix C). None of the e-interventions was identified as a commercial product. Because these studies varied considerably in participants enrolled, interventions, and outcomes reported, we describe each separately below.

Table 6 Study Characteristics (KQ 3)

Study | Setting | Mean Age (SD) | N | Inclusion Criteria | E-Intervention | Control | Follow-up Interval | Outcomes | Overall Risk of Bias
Bischof, 2008^33^ | Primary care | 36.5 (13.5) | 408 (124 AUD subgroup) | AUDIT ≥5 and ≥2 binge episodes in past 4 weeks or >20 g (F) or 30 g (M) daily | Computerized feedback on alcohol use and 1-4 telephonic MI sessions | Waitlist | 12 months | Alcohol consumption | Moderate
Gustafson, 2014^52^ | Residential care facilities | 38.4 (10.4) | 349 | Completing residential treatment program for DSM-IV alcohol dependence | Multicomponent smartphone application offered for 8 months | Treatment as usual | 12 months | Alcohol consumption Social effects | Moderate
Mundt, 2006^60^ | Residential facility | 41.9 (9.2) | 60 | Completing residential treatment program for AUD | IVR prompted or ad lib | No IVR | 6 months | Alcohol consumption HRQOL Social effects | High

Abbreviations: AUD=alcohol use disorder; AUDIT=Alcohol Use Disorders Identification Test; DSM-IV=Diagnostic and Statistical Manual of Mental Disorders, 4^th^ edition; E-Intervention=electronic intervention; F=female; HRQOL=health-related quality of life; IVR=interactive voice response; KQ=key question; M=male; MI=motivational interviewing; N=number of participants; SD=standard deviation

Gustafson and colleagues52 recruited 349 participants from 5 U.S. residential treatment facilities who were completing treatment for alcohol dependence. The average age was 38.4 (SD 10.4) years old, 39% were women, 80% were white, and mean years of education were not reported. At discharge from residential treatment, participants were randomized to: 1) the multicomponent Addiction-Comprehensive Health Enhancement Support System (A-CHESS) for 8 months; or 2) treatment as usual. Intervention participants received a smartphone with the A-CHESS application, which included both static and interactive features, mobile phone service, and a data plan. Two hundred and eighty-six (286) smartphones were given to the 170 intervention participants due to malfunctioning, lost, stolen, and damaged phones. Participants could elect to share data from the A-CHESS application with their counselors: 93.5% shared data from the weekly Brief Addiction Monitor, and 41.9% shared data about alcohol relapse. At 12-month follow-up, the intervention group had higher rates of abstinence (OR 1.94; 95% CI, 1.14 to 3.31) and fewer risky drinking days per 30-day period (MD -1.47; 95% CI, -0.13 to -2.81). There were no significant effects on any of the 8 items measuring negative consequences of drinking.

Bischof and colleagues33 recruited 408 participants from German primary care practices with alcohol problems ranging from a positive alcohol screen to alcohol dependence established by a criterion-based structured interview. Average age was 36.5 (SD 13.5) years old, 32% were women, race was not reported, and mean years of education were 10.5 (2.5). We report on the subgroup (n=124) with alcohol dependence. Participants were randomized to: 1) a no-intervention control; 2) computerized feedback plus 4 brief counseling sessions of 30 minutes each delivered by telephone; or 3) computerized feedback and 1 to 4 brief counseling sessions of 30 minutes each delivered by telephone. For the latter group, counseling sessions were discontinued when the patient met criteria for a reduction in alcohol consumption and indicated high self-efficacy to maintain the reduction in alcohol consumption. The computerized feedback was based on the transtheoretical model of behavior change, and telephonic counseling was based on motivational interviewing and delivered by a trained psychologist. At 12-month follow-up, the intervention groups did not differ from the control group in alcohol consumption (p=0.62) or in the proportion meeting criteria for binge drinking (54.5% intervention vs 50% control; p=0.69). Other outcomes prioritized for this review were not reported.

Mundt et al60 evaluated the effect of an IVR system in 60 participants treated for alcohol dependence at a Wisconsin residential treatment facility. Average age was 41.9 (SD 9.1) years, 45% were women, 95% were white race, and mean years of education were not reported. At discharge from residential treatment, participants were randomized to: 1) a no-intervention control; 2) prompted use of the IVR system; or 3) ad libitum use of the IVR system. The prompted group was called and encouraged to use the system if they failed to make a daily call to the IVR system for 2 consecutive days. The IVR system included assessments of drinking status, alcohol cravings, self-efficacy, difficulty coping, and risk of relapse. Participants were directed to modules that incorporated tailored feedback based on patterns of alcohol consumption: resolve not to drink module, drinking reasons module, and cognitive behavioral advice module. The system included voice mail capability and allowed participants to request a personal phone call from the coordinator. At 6-month follow-up, intervention subjects had placed a mean of 51.4 (SD 22.6) IVR calls; mean calls were higher (p=not statistically significant [NS]) in the ad libitum group. Self-reported abstinence was reported in 20 of 30 intervention subjects (67%) and 13 of 18 control subjects (72%; p=not reported [NR]). There were no statistically significant intervention effects on functional status, or work and social adjustment.

### Summary of Findings

Three trials conducted in participants with alcohol used disorders found positive effects from a multicomponent smartphone application, but no intervention effects from a computerized feedback system coupled with telephonic counseling or an IVR system.

### Quality of Evidence for KQ 3

The 3 trials were judged to be at moderate33,52 or high60 risk of bias (Appendix C). Using the GRADE framework,69 the SOE is low (moderate risk of bias, imprecise effects) that a multicomponent smartphone intervention decreases alcohol use in adults with alcohol use disorders. The SOE is insufficient for the effects of IVR and computerized feedback couple with brief telephone counseling.

## KEY QUESTION 4 For adults who misuse alcohol, are at high risk of AUD, or have a diagnosis of AUD, what are the effects of e-interventions alone or used in combination with face-to-face therapy compared with face-to-face therapy alone?

### Key Points

- Six trials (1090 participants) compared e-interventions alone or in combination with face-to-face brief motivational interviewing (BMI) to BMI alone. All studies enrolled individuals with alcohol misuse, but varied markedly with regard to setting and subject and intervention characteristics.
- Combination of e-interventions plus BMI versus BMI alone: Two studies in adults compared BMI plus IVR to BMI alone and found no improvement in primary drinking outcomes with the addition of IVR. A subgroup analysis found benefit with combined IVR and BMI for HIV-positive adults who met DSM-IV criteria for alcohol dependence. In a study of college students, the addition of an e-intervention utilizing 1 to 2 sessions of personalized normative feedback (PNF) plus psychoeducation to BMI versus BMI alone showed no improvement in 12-month drinking outcomes.
- E-interventions alone versus BMI alone: In 3 head-to-head comparisons, all involving college students, e-interventions were associated with significantly heavier alcohol intake at follow-up (ranging from 50 to 81 g greater weekly consumption) compared with BMI. Binge drinking frequency was higher in e-intervention participants than in BMI participants (MD 2 to 2.5 more episodes per month).
- This diverse group of studies did not find a benefit of e-interventions alone or as an adjunct to face-to-face BMI, compared with face-to-face BMI alone for college students or midlife primary care patients who misuse alcohol.

### Study Characteristics

Six trials (Table 7), described in 5 papers and involving 1090 participants, compared e-interventions alone or used in combination with face-to-face BMI to face-to-face BMI alone.36,45,48,54,55 The paper by Monahan and colleagues45 reported results from 2 separate trials. Two trials (508 participants), conducted with midlife patients in primary care settings, compared the combination of IVR plus face-to-face BMI to face-to-face BMI alone.54,55 Four trials (582 participants) focused on college students in their late teens.36,45,48 Three of these compared e-interventions to BMI.36,45 The fourth compared the combination of an e-intervention plus BMI to BMI alone.48 All studies enrolled subjects based on recent alcohol misuse (eg, ≥1 episode of heavy drinking in the past 14 or 30 days, acute intoxication, or alcohol policy violation) rather than specific evidence of a diagnosable AUD. Thus, subject inclusion criteria in these studies are similar to those used in the studies described in KQ 2. One study used DSM-IV criteria to assess enrolled subjects, allowing subgroup analysis for those with a diagnosis of alcohol dependence.54 Two studies48,54 were judged to be at low risk of bias, and 4 studies were assessed as being at moderate risk of bias.36,45,55

Table 7 Study Characteristics (KQ 4)

Author | Setting | Mean Age | N | Inclusion Criteria (M/F) | e-Intervention | Control | Follow-up Interval | Outcomes | Overall Risk of Bias
Barnett 2007^48^ | College health service | 18.8 | 225 | Referred due to intoxication or violation | Alcohol 101 + BMI | BMI ± 25-min booster | 12 months | Alcohol consumption Social effects | Low
Hasin, 2013^54^ | HIV primary care | 46 | 170 | >3 drinks once in 30 days | IVR daily × 60 days + BMI | BMI, 20-25 min | 12 months | Alcohol consumption | Low
Helzer, 2008^55^ | Primary care | 45 | 338 | >NIAAA drinking limits or CAGE 1+ | IVR daily × 6 months + BMI ± PNF | BMI ± mailed PNF | 6 months | Alcohol consumption | Moderate
Monahan, 2013a=Study 1^45^ | College health service | 21.2 | 73 | >4/3 drinks once in past 30 days | Alcohol 101 | BMI 1 × 50-min session | 6 months | Alcohol consumption | Moderate
Monahan, 2013b=Study 2^45^ | College course | 18.6 | 91 | >4/3 drinks once in past 30 days | e-CHUG | BMI | 6 months | Alcohol consumption | Moderate
Walters, 2009^36^ | College campus | 19.8 | 193 | >4/3 drinks once in past 14 days | e-CHUG | BMI ± PNF | 6 months | Alcohol consumption Social effects | Moderate

Abbreviations: BMI=brief motivational interviewing; CAGE=Cut down/Annoyed/Guilty/Eye-opener; e-CHUG=Electronic Check-Up to Go; F=female; IVR=interactive voice response; KQ=key question; M=male; min=minute(s); NIAA=National Institutes of Alcoholism and Alcohol Abuse; PNF=personalized normative feedback

### E-Intervention Characteristics

E-interventions studied were daily IVR calls for periods of 60 days54 or 6 months;55 Alcohol 101 interactive CD-ROM;45,48 and e-CHUG, a web-based interactive program.36,45 Comparator face-to-face counseling consisted of single-session of BMI; 2 studies included a brief booster or follow-up counseling sessions. The extent of counselor experience, training, supervision, and fidelity monitoring varied across the 6 studies. Characteristics of the e-interventions evaluated are summarized in Table 8.

Table 8 Characteristics of E-Interventions (KQ 4)

Characteristic | Adult studies (n=2; 508 participants) | Student studies (n=4; 582 participants)
Delivery location:
Primary care | 2 | 0
College health services | 0 | 2
College campus | 0 | 2
Intervention design:
BMI plus e-intervention | 2 | 1
e-intervention alone | 0 | 3
Intervention name:
Alcohol 101 | 0 | 2
e-CHUG | 0 | 2
Not named | 2 | 0
Delivery Mode:
IVR | 2 | 0
Accessed online | 0 | 2
Accessed on desktop computer | 0 | 2
Number of e-intervention sessions:
1 | 0 | 3
>1 | 2 (IVR daily) | 1
In-person BMI sessions:
1 | 1 | 3
>1 | 1 | 1
Outcomes:
Alcohol consumption | 2 | 4
HRQOL | 0 | 0
Social/legal effects | 0 | 2
Risk of bias:
Low | 1 | 1
Moderate | 1 | 3

Abbreviations: BMI=brief motivational interviewing; e-CHUG=Electronic Check-Up to Go; HRQOL=health-related quality of life; IVR=interactive voice response; KQ=key question

### Alcohol Consumption

#### E-intervention Alone versus Face-to-Face Counseling (3 Trials)

E-interventions were compared with face-to-face interventions only in college student populations. In all 3 head-to-head comparisons of e-interventions versus face-to-face BMI, e-interventions were associated with poorer alcohol outcomes than was face-to-face counseling.36,45

Monahan et al45 reported 2 trials comparing e-interventions to BMI in college students recruited in a campus health service. The entry criterion for both studies was at least one episode of consuming >5 drinks (males) or >4 drinks (females) in the past month. In Study 1, 60 subjects were randomized to the Alcohol 101 CD-ROM or face-to-face BMI. In Study 2, 68 subjects were randomized to an interactive, web-based program that included personalized feedback (e-CHUG) or face-to-face BMI. At 6-month follow-up in Study 1, participants receiving the e-intervention were consuming more alcohol per week than those assigned to face-to-face BMI, but results were statistically insignificant (MD 52.2 g/week; 95% CI, -35.7 to 140.1). A similar difference was found in Study 2 (MD 50.1 g/week; 95% CI, -52.6 to 152.8). In both studies, the frequency of binge drinking at 6 months was higher in those receiving the e-intervention, but results were statistically significant only in Study 2. Study 1 e-intervention participants reported 5.5 (SD 6.7) past-month binge episodes versus 3.5 (SD 3.3) for BMI participants (MD 2.0; 95% CI, -0.57 to 4.7). In Study 2, e-intervention participants reported 5.8 (SD 5.5) past-month binge episodes versus 3.3 (SD 4.9) with BMI (MD 2.5; 95% CI, 0.14 to 5.01).

Walters et al36 studied college students (average age 19.8 years) reporting at least one episode of consuming ≥5 drinks (males) or ≥4 drinks (females) in the past 2 weeks. Two hundred and seventy-nine subjects were randomized to one of 4 conditions: 1) assessment only; 2) e-CHUG; 3) BMI without structured assessment feedback; 4) BMI that incorporated PNF derived from a structured assessment. The assessment-only group is not relevant to this KQ. At 6-month follow-up, e-intervention participants were consuming 168.9 g of alcohol per week (SD 172.3) versus 162.3 (SD 295.9) for BMI only and 142.7 (SD 133.7) for BMI with feedback. In an analysis that adjusted for differences in baseline values, participants assigned to the e-intervention reported significantly higher alcohol consumption compared with those receiving BMI with feedback (5.79 drinks per week, standard error of the mean [SEM] 2.05, p=0.005).

#### E-intervention Plus Face-to-Face Counseling versus Face-to-Face Counseling Alone (3 Trials)

In the 3 trials comparing e-interventions plus face-to-face counseling versus face-to-face counseling alone, the addition of an e-intervention was not associated with decreased alcohol consumption.48,54,55 Two studies enrolled midlife adult patients recruited from primary care settings,54,55 and one recruited participants from a college health service.48

Helzer et al55 studied adult primary care patients (mean age 45) whose average alcohol consumption exceeded NIAAA recommended drinking limits or who scored >1 positive on the Cut down/Annoyed/Guilty/Eye-opener (CAGE) questionnaire. The study was conducted across 15 primary care clinics, involving 112 providers who were trained in conducting brief intervention for excessive alcohol use. All potential subjects received a face-to-face brief intervention delivered by their primary care provider and were then invited to participate in the study, in which 338 subjects were randomized to: 1) face-to-face brief intervention only; 2) face-to-face brief intervention plus 6 months of daily IVR follow-up; or 3) face-to-face brief intervention plus 6 months of daily IVR follow-up plus feedback. Feedback consisted of a mailed, printed graph showing daily consumption as reported via IVR in comparison with the participant's stated drinking goal, accompanied by a personalized note from Dr. Helzer highlighting the importance of the information. Two hundred and seventy-three subjects (81%) completed the 6-month follow-up interview, with no significant differences in follow-up rate between treatment groups. At 6-month follow-up, mean weekly drinking levels were 25.0 standard drinks (SEM 1.3) in subjects randomized to IVR; 22.4 (SEM 1.4) standard drinks in subjects assigned to IVR plus feedback; and 18.3 (SEM 1.3) for those assigned to brief intervention alone. In a preplanned comparison of all IVR participants (combining those with and without feedback) versus brief intervention-only participants, IVR was associated with significantly heavier weekly drinking (22.6 drinks per week, SEM 0.8) compared with brief intervention only (18.3 drinks, SEM 1.3; p=0.01).

Hasin et al54 compared BMI plus IVR to BMI alone in a primary care clinic serving HIV-positive individuals (mean age 46). The inclusion criterion was consumption of >4 standard drinks on one occasion within the past 30 days. One-hundred and seventy subjects were randomized to a 20- to 25-minute BMI session only versus BMI plus daily IVR for 60 days (BMI+IVR). At 12-month follow-up, there was no difference between groups for the primary outcome measure, number of drinks per drinking day. In subgroup analysis, subjects who met criteria for a DSM-IV diagnosis of alcohol dependence, drinks per drinking day were lower in the BMI+IVR than the BMI-only group (p<0.03).

Barnett et al48 compared the combination of BMI plus the Alcohol 101 CD-ROM program with BMI alone in college students (n=225) who were referred to campus health service due to an episode of acute intoxication or violation of campus alcohol policy. At 12-month follow-up, there were no between-group differences in alcohol consumption or alcohol related social or legal problems.

### Other Outcomes

Other outcomes were reported infrequently. Two studies conducted in college students reported the effects of e-interventions on social outcomes at 6^36^ or 12 months.48 Neither study found a differential effect between BMI and the e-intervention for this outcome. No study reported effects on HRQOL, alcohol-related health problems, medical utilization, or adverse effects of treatment.

### Summary of Findings

Six trials (1090 participants) compared e-interventions alone or in combination with face-to-face BMI to BMI alone. Studies were too diverse to compute summary estimates of effect. IVR in combination with BMI was the only e-intervention compared to face-to-face treatment in non-collegiate populations. The addition of IVR did not decrease alcohol consumption in 2 trials that enrolled midlife primary care patients with alcohol misuse. In collegiate populations, BMI was generally more effective than e-interventions alone in decreasing alcohol consumption.

### Quality of Evidence for KQ 4

Two trials were judged to be at low risk of bias and 4 at moderate risk (Appendix C). For e-interventions compared with face-to-face treatment, we judged the SOE as low. These studies had moderate risk of bias, were conducted in collegiate populations, and effect estimates did not exclude a difference of 3 standard drinks per week or a SMD of ≤0.4, the thresholds we set for a precise estimate of effect. When evaluating the overall SOE, we considered a difference of 3 standard U.S. drinks/week or an SMD ≥0.4 as clinically significant and defined precise effects as those with 95% CIs that excluded smaller effects. For combined e-interventions plus face-to- face treatment versus face-to-face alone, we judged the SOE to be low for effects on alcohol consumption, and insufficient for effects on social and legal outcomes. These studies had moderate risk of bias and primarily used IVR interventions, which have important differences from other e-interventions because the interface is through a telephone or analog line.