# REFERENCES

1 U.S. Burden of Disease Collaborators. The state of US health, 1990-2010: burden of diseases, injuries, and risk factors. JAMA. 2013;310(6):591-608. [pmid: 23842577].
2 Institute of Medicine. Broadening the Base of Treatment of Alcohol Problems: Report of a Study by a Committee of the Institute of Medicine, Division of Mental Health and Behavioral Medicine. Washington, DC. National Academies Press. 1990.
3 Cuijpers P, Riper H, Lemmers L. The effects on mortality of brief interventions for problem drinking: a meta-analysis. Addiction. 2004;99(7):839-845. [pmid: 15200579].
4 Grant BF, Stinson FS, Dawson DA, et al. Prevalence and co-occurrence of substance use disorders and independent mood and anxiety disorders: results from the National Epidemiologic Survey on Alcohol and Related Conditions. Arch Gen Psychiatry. 2004;61(8):807-816. [pmid: 15289279].
5 World Health Organization. Global status report on alcohol and health. Geneva. WHO Press. 2011. http://www.drugsandalcohol.ie/14675/1/Global_status_report_on_alcohol_and_health..pdf. July 19, 2014.
6 Franck J, Jayaram-Lindstrom N. Pharmacotherapy for alcohol dependence: status of current treatments. Curr Opin Neurobiol. 2013;23(4):692-699. [pmid: 23810221].
7 Centers for Disease Control and Prevention. FastStats: alcohol use. http://www.cdc.gov/nchs/fastats/alcohol.htm. Last updated: February 28, 2014. July 18, 2014.
8 Jonas DE, Garbutt JC, Amick HR, et al. Behavioral counseling after screening for alcohol misuse in primary care: a systematic review and meta-analysis for the U.S. Preventive Services Task Force. Ann Intern Med. 2012;157(9):645-654. http://annals.org/article.aspx?articleid=1361859&resultClick=3. September 25, 2014. [pmid: 23007881].
9 Rehm J, Mathers C, Popova S, Thavorncharoensap M, Teerawattananon Y, Patra J. Global burden of disease and injury and economic cost attributable to alcohol use and alcohol-use disorders. Lancet. 2009;373(9682):2223-2233. [pmid: 19560604].
10 U.S. Census Bureau. S2101. Veteran status. 2010 American Community Survey 1-year estimates. Retrieved July 22, 2014, from http://factfinder2.census.gov/faces/tableservices/jsf/pages/productview.xhtml?pid=ACS_10_1YR_S2101&prodType=table.
11 Wagner TH, Harris KM, Federman B, Dai L, Luna Y, Humphreys K. Prevalence of substance use disorders among veterans and comparable nonveterans from the National Survey on Drug Use and Health. Psychol Serv. 2007;4(3):149-157.
12 Hawkins EJ, Malte CA, Baer JS, Kivlahan DR. Prevalence, predictors, and service utilization of patients with recurrent use of Veterans Affairs substance use disorder specialty care. J Subst Abuse Treat. 2012;43(2):221-230. [pmid: 22197302].
13 Yu W, Ravelo A, Wagner TH, et al. Prevalence and costs of chronic conditions in the VA health care system. Med Care Res Rev. 2003;60(3 Suppl):146S-167S. [pmid: 15095551].
14 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders. 5th ed. Arlington, VA. American Psychiatric Publishing. 2013.
15 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders. 4th ed. Washington, DC. American Psychiatric Association. 1994.
16 Barry KL, Blow FC, Willenbring ML, McCormick R, Brockmann LM, Visnic S. Use of alcohol screening and brief interventions in primary care settings: implementation and barriers. Subst Abus. 2004;25(1):27-36. [pmid: 15201109].
17 Nilsen P. Brief alcohol intervention—where to from here? Challenges remain for research and practice. Addiction. 2010;105(6):954-959. [pmid: 20121717].
18 Williams EC, Johnson ML, Lapham GT, et al. Strategies to implement alcohol screening and brief intervention in primary care settings: a structured literature review. Psychol Addict Behav. 2011;25(2):206-214. [pmid: 21517141].
19 Pew Research Internet Project. Health fact sheet. http://www.pewinternet.org/fact-sheets/health-fact-sheet/. September 5, 2014.
20 Cunningham JA, Selby PL, Kypri K, Humphreys KN. Access to the Internet among drinkers, smokers and illicit drug users: is it a barrier to the provision of interventions on the World Wide Web?. Med Inform Internet Med. 2006;31(1):53-58. [pmid: 16754367].
21 Vernon ML. A review of computer-based alcohol problem services designed for the general public. J Subst Abuse Treat. 2010;38(3):203-211. [pmid: 20015607].
22 Tait RJ, Christensen H. Internet-based interventions for young people with problematic substance use: a systematic review. Med J Aust. 2010;192(11 Suppl):S15-21. [pmid: 20528701].
23 Carey KB, Scott-Sheldon LA, Elliott JC, Bolles JR, Carey MP. Computer-delivered interventions to reduce college student drinking: a meta-analysis. Addiction. 2009;104(11):1807-1819. [pmid: 19744139].
24 Carey KB, Scott-Sheldon LA, Elliott JC, Garey L, Carey MP. Face-to-face versus computer-delivered alcohol interventions for college drinkers: a meta-analytic review, 1998 to 2010. Clin Psychol Rev. 2012;32(8):690-703. [pmid: 23022767].
25 Bewick BM, Trusler K, Barkham M, Hill AJ, Cahill J, Mulhern B. The effectiveness of web-based interventions designed to decrease alcohol consumption—a systematic review. Prev Med. 2008;47(1):17-26. [pmid: 18302970].
26 Khadjesari Z, Murray E, Hewitt C, Hartley S, Godfrey C. Can stand-alone computer-based interventions reduce alcohol consumption? A systematic review. Addiction. 2011;106(2):267-282. [pmid: 21083832].
27 Riper H, Spek V, Boon B, et al. Effectiveness of E-self-help interventions for curbing adult problem drinking: a meta-analysis. J Med Internet Res. 2011;13(2):e42. [pmid: 21719411].
28 Rooke S, Thorsteinsson E, Karpin A, Copeland J, Allsop D. Computer-delivered interventions for alcohol and tobacco use: a meta-analysis. Addiction. 2010;105(8):1381-1390. [pmid: 20528806].
29 Lefebvre C, Manheimer E, Glanville J. Chapter 6: Searching for studies. Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. (updated March 2011). The Cochrane Collaboration. 2011. www.cochrane-handbook.org. July 22, 2014.
30 Elliott JC, Carey KB, Bolles JR. Computer-based interventions for college drinking: a qualitative review. Addict Behav. 2008;33(8):994-1005. [pmid: 18538484].
31 White A, Kavanagh D, Stallman H, et al. Online alcohol interventions: a systematic review. J Med Internet Res. 2010;12(5):e62. [pmid: 21169175].
32 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. http://www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=318. July 22, 2014.
33 Bischof G, Grothues JM, Reinhardt S, Meyer C, John U, Rumpf HJ. Evaluation of a telephone-based stepped care intervention for alcohol-related disorders: a randomized controlled trial. Drug Alcohol Depend. 2008;93(3):244-251. [pmid: 18054443].
34 Kypri K, Langley JD, Saunders JB, Cashell-Smith ML, Herbison P. Randomized controlled trial of web-based alcohol screening and brief intervention in primary care. Arch Intern Med. 2008;168(5):530-536. [pmid: 18332300].
35 Neighbors C, Lewis MA, Atkins DC, et al. Efficacy of web-based personalized normative feedback: a two-year randomized controlled trial. J Consult Clin Psychol. 2010;78(6):898-911. [pmid: 20873892].
36 Walters ST, Vader AM, Harris TR, Field CA, Jouriles EN. Dismantling motivational interviewing and feedback for college drinkers: a randomized clinical trial. J Consult Clin Psychol. 2009;77(1):64-73. [pmid: 19170454].
37 Gual A, Martos AR, Lligona A, Llopis JJ. Does the concept of a standard drink apply to viticultural societies?. Alcohol Alcohol. 1999;34(2):153-160. [pmid: 10344775].
38 Miller WR, Heather N, Hall W. Calculating standard drink units: international comparisons. Br J Addict. 1991;86(1):43-47. [pmid: 2009396].
39 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-188. [pmid: 3802833].
40 Knapp G, Hartung J. Improved tests for a random effects meta-regression with a single covariate. Stat Med. 2003;22(17):2693-2710. [pmid: 12939780].
41 Cohen J. Statistical Power Analysis for the Behavioral Sciences. 2nd edition. Hillside, NJ. Erlbaum Associates. 1988.
42 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539-1558. [pmid: 12111919].
43 Fu R, Gartlehner G, Grant M, et al. Conducting Quantitative Synthesis When Comparing Medical Interventions: AHRQ and the Effective Health Care Program. Agency for Healthcare Research and Quality. Methods Guide for Comparative Effectiveness Reviews. [posted October 2010]. Rockville, MD. Available at: http://effectivehealthcare.ahrq.gov/. September 5, 2014.
44 Viechtbauer W. Conducting meta-analyses in R with the metafor package. Journal of Statistical Software. 2010;36(3):1-48.
45 Monahan CJ, McDevitt-Murphy ME, Dennhardt AA, Skidmore JR, Martens MP, Murphy JG. The impact of elevated posttraumatic stress on the efficacy of brief alcohol interventions for heavy drinking college students. Addict Behav. 2013;38(3):1719-1725. [pmid: 23261489].
46 Assistance Publique - Hôpitaux de Paris. Effect of an Interactive Computer Program to Prevent Alcohol Misuse. A Multicentre Randomized Controlled Trial. The BREVALCO Study. ClinicalTrials.gov [Internet]. Bethesda, MD. National Library of Medicine (US). http://clinicaltrials.gov/show/NCT00658398. September 11, 2014. NLM Identifier: NCT00658398.
47 Region Skane. Development of IVR and WEB Alcohol Interventions. ClinicalTrials.gov [Internet]. Bethesda, MD. National Library of Medicine (US). http://clinicaltrials.gov/show/NCT01923246. September 11, 2014. NLM Identifier: NCT01923246.
48 Barnett NP, Murphy JG, Colby SM, Monti PM. Efficacy of counselor vs. computer-delivered intervention with mandated college students. Addict Behav. 2007;32(11):2529-2548. [pmid: 17707594].
49 Boon B, Risselada A, Huiberts A, Riper H, Smit F. Curbing alcohol use in male adults through computer generated personalized advice: randomized controlled trial. J Med Internet Res. 2011;13(2):e43. [pmid: 21719412].
50 Cucciare MA, Weingardt KR, Ghaus S, Boden MT, Frayne SM. A randomized controlled trial of a web-delivered brief alcohol intervention in Veterans Affairs primary care. J Stud Alcohol Drugs. 2013;74(3):428-436. [pmid: 23490572].
51 Cunningham JA, Wild TC, Cordingley J, van Mierlo T, Humphreys K. A randomized controlled trial of an internet-based intervention for alcohol abusers. Addiction. 2009;104(12):2023-2032. [pmid: 19922569].
52 Gustafson DH, McTavish FM, Chih MY, et al. A smartphone application to support recovery from alcoholism: a randomized clinical trial. JAMA Psychiatry. 2014;71(5):566-572. [pmid: 24671165].
53 Hansen AB, Becker U, Nielsen AS, Gronbaek M, Tolstrup JS, Thygesen LC. Internet-based brief personalized feedback intervention in a non-treatment-seeking population of adult heavy drinkers: a randomized controlled trial. J Med Internet Res. 2012;14(4):e98. [pmid: 22846542].
54 Hasin DS, Aharonovich E, O'Leary A, et al. Reducing heavy drinking in HIV primary care: a randomized trial of brief intervention, with and without technological enhancement. Addiction. 2013;108(7):1230-1240. [pmid: 23432593].
55 Helzer JE, Rose GL, Badger GJ, et al. Using interactive voice response to enhance brief alcohol intervention in primary care settings. J Stud Alcohol Drugs. 2008;69(2):251-258. [pmid: 18299766].
56 Hester RK, Delaney HD, Campbell W. The college drinker's check-up: outcomes of two randomized clinical trials of a computer-delivered intervention. Psychol Addict Behav. 2012;26(1):1-12. [pmid: 21823769].
57 Kypri K, Hallett J, Howat P, et al. Randomized controlled trial of proactive web-based alcohol screening and brief intervention for university students. Arch Intern Med. 2009;169(16):1508-1514. [pmid: 19752409].
58 Kypri K, Saunders JB, Williams SM, et al. Web-based screening and brief intervention for hazardous drinking: a double-blind randomized controlled trial. Addiction. 2004;99(11):1410-1417. [pmid: 15500594].
59 Moreira MT, Oskrochi R, Foxcroft DR. Personalised normative feedback for preventing alcohol misuse in university students: Solomon three-group randomised controlled trial. PLoS One. 2012;7(9):e44120. [pmid: 22984466].
60 Mundt JC, Moore HK, Bean P. An interactive voice response program to reduce drinking relapse: a feasibility study. J Subst Abuse Treat. 2006;30(1):21-29. [pmid: 16377449].
61 Neighbors C, Larimer ME, Lewis MA. Targeting misperceptions of descriptive drinking norms: efficacy of a computer-delivered personalized normative feedback intervention. J Consult Clin Psychol. 2004;72(3):434-447. [pmid: 15279527].
62 Neumann T, Neuner B, Weiss-Gerlach E, et al. The effect of computerized tailored brief advice on at-risk drinking in subcritically injured trauma patients. J Trauma. 2006;61(4):805-814. [pmid: 17033544].
63 Riper H, Kramer J, Smit F, Conijn B, Schippers G, Cuijpers P. Web-based self-help for problem drinkers: a pragmatic randomized trial. Addiction. 2008;103(2):218-227. [pmid: 18199300].
64 Schulz DN, Candel MJ, Kremers SP, Reinwand DA, Jander A, de Vries H. Effects of a Web-based tailored intervention to reduce alcohol consumption in adults: randomized controlled trial. J Med Internet Res. 2013;15(9):e206. [pmid: 24045005].
65 Sinadinovic K, Wennberg P, Berman AH. Targeting problematic users of illicit drugs with Internet-based screening and brief intervention: a randomized controlled trial. Drug Alcohol Depend. 2012;126(1-2):42-50. [pmid: 22613182].
66 Voogt CV, Poelen EA, Kleinjan M, Lemmers LA, Engels RC. The effectiveness of the ‘what do you drink’ web-based brief alcohol intervention in reducing heavy drinking among students: a two-arm parallel group randomized controlled trial. Alcohol Alcohol. 2013;48(3):312-321. [pmid: 23303466].
67 Wallace P, Murray E, McCambridge J, et al. On-line randomized controlled trial of an internet based psychologically enhanced intervention for people with hazardous alcohol consumption. PLoS One. 2011;6(3):e14740. [pmid: 21408060].
68 Collins SE, Witkiewitz K, Larimer ME. The theory of planned behavior as a predictor of growth in risky college drinking. J Stud Alcohol Drugs. 2011;72(2):322-332. [pmid: 21388605].
69 Guyatt G, Oxman AD, Akl EA, et al. GRADE guidelines: 1. Introduction-GRADE evidence profiles and summary of findings tables. J Clin Epidemiol. 2011;64(4):383-394. [pmid: 21195583].
70 O'Donnell A, Anderson P, Newbury-Birch D, et al. The impact of brief alcohol interventions in primary healthcare: a systematic review of reviews. Alcohol Alcohol. 2014;49(1):66-78. [pmid: 24232177].
71 Lapham GT, Hawkins EJ, Chavez LJ, et al. Feedback from recently returned veterans on an anonymous web-based brief alcohol intervention. Addict Sci Clin Pract. 2012;7(1):17. [pmid: 23186354].
72 Griffiths RD, Stone A, Tran DT, Fernandez RS, Ford K. Drink a little; take a few drugs: do nurses have knowledge to identify and manage in-patients at risk of drugs and alcohol?. Drug Alcohol Rev. 2007;26(5):545-552. [pmid: 17701518].
73 Happell B, Carta B, Pinikahana J. Nurses' knowledge, attitudes and beliefs regarding substance use: a questionnaire survey. Nurs Health Sci. 2002;4(4):193-200. [pmid: 12406206].
74 Nygaard P, Aasland OG. Barriers to implementing screening and brief interventions in general practice: findings from a qualitative study in Norway. Alcohol Alcohol. 2011;46(1):52-60. [pmid: 21059696].
75 Brief DJ, Rubin A, Keane TM, et al. Web intervention for OEF/OIF veterans with problem drinking and PTSD symptoms: a randomized clinical trial. J Consult Clin Psychol. 2013;81(5):890-900. [pmid: 23875821].