# METHODS

## TOPIC DEVELOPMENT

We followed a standard protocol for this review. The topic was nominated after a process that included a preliminary review of published peer-reviewed literature and consultation with investigators, Veterans Affairs (VA) and non-VA experts, and key stakeholders (Mental Health Web Services, Mental Health Services, and Mental Health Quality Enhancement Research Initiative [QUERI]).

The key questions (KQs) are:

- KQ 1: For e-interventions targeting adults who misuse alcohol or who have a diagnosis of AUD, what level, type, and modality of user support is provided (eg, daily telephone calls, weekly email correspondence), by whom (eg, professional counselor, technical support staff), and in what clinical context (adjunct to therapy or primary intervention)?
- KQ 2: For adults who misuse alcohol but do not meet diagnostic criteria for AUD, what are the effects of e-interventions compared with inactive controls?
- KQ 3: For adults at high risk of AUD (eg, AUDIT-C ≥8), or who have a diagnosis of AUD, what are the effects of e-interventions compared with inactive controls?
- KQ 4: For adults who misuse alcohol, are at high risk of AUD, or have a diagnosis of AUD, what are the effects of e-interventions alone or used in combination with face-to-face therapy compared with face-to-face therapy alone?

## SEARCH STRATEGY

We conducted a primary review of the literature by systematically searching, reviewing, and analyzing the scientific evidence as it pertains to the KQs. To identify relevant articles, in consultation with an expert librarian, we searched MEDLINE (via PubMed), The Cochrane Library, Embase, and PsycINFO from January 1, 2000 to August 18, 2014, for peer-reviewed publications of trials that compared e-interventions with a waitlist control, usual care, or face-to-face therapy in adults who misuse alcohol or who have a diagnosis of AUD.

We used Medical Subject Heading (MeSH) terms and selected free-text terms for the conditions of interest; cognitive-behavioral therapy and closely related therapies, including brief counseling and health education; and the electronic delivery mode, including computer-assisted, Internet, and terms for mobile devices. We added validated search terms for RCTs.29 We limited the search to RCTs published in English. The exact search strategies used are provided in Appendix A. We further searched the bibliographies of exemplar trials and systematic reviews for missed publications.23-28,30,31

To assess for possible publication bias, we searched ClinicalTrials.gov (www.clinicaltrials.gov) to identify completed but unpublished studies meeting our eligibility criteria.

All citations were imported into 2 electronic databases (for referencing, EndNote^®^ Version X5, Thomson Reuters, Philadelphia, PA; for data abstraction, DistillerSR; Evidence Partners Inc., Manotick, ON, Canada).

## STUDY SELECTION

Using prespecified inclusion and exclusion criteria, 2 investigators assessed titles and abstracts for relevance to the KQs. Full-text articles identified by either investigator as potentially relevant were retrieved for further review and examined by 2 investigators against the eligibility criteria. Disagreements on inclusion, exclusion, or the major reason for exclusion were resolved by discussion or by a third investigator. The criteria to screen articles for inclusion or exclusion at both the title-and-abstract and full-text screening stages are detailed in Table 2. In addition, trials with 3 or more arms were examined for appropriateness of all arms for inclusion. For example, any active arm that did not include an e-intervention or evidence-based face-to-face treatment was not abstracted for inclusion in the analysis.

Table 2 Inclusion and Exclusion Criteria

Study Characteristic | Inclusion Criteria | Exclusion Criteria
Population | Adults 18 years or older with alcohol misuse (eg, positive alcohol screen; KQ 2), at high risk of AUD, or with diagnosis of AUD (KQ 3) | Pregnant women
Intervention | Intervention must be a computer-based therapy adhering to evidence-based treatment principles and providing individually delivered treatment for alcohol misuse delivered by CD-ROM, web-based, IVR, mobile phones, or in-home electronic devices (eg, Health Buddy™) and may be combined with various levels of supplementary human support. | Interventions targeted at dyads (eg, couple) or primary prevention Computerized screening only
Comparator | The comparator for KQ 2 and KQ 3 was usual care not involving psychotherapy; waitlist; or information or attention control. For KQ 4, the comparator was face-to-face treatment. | Any comparator where the effect of the electronic aspect of the intervention could not be isolated
Outcome | Studies must report effects on at least one of the following relevant outcomes: alcohol consumption, alcohol-related health problems, alcohol-related legal or social problems, HRQOL, functional status measures, medical utilization, or adverse effects from treatment. | –
Timing | Outcomes reported at ≥6 months from randomization and initiation of intervention | Outcomes reported at <6 months
Setting | Outpatients in any setting (general medical, emergency room, and community) or participants not engaged in clinical care who are enrolled through self-assessments. We included studies where enrollment was inpatient but the majority of the intervention was delivered outpatient. | Inpatient settings for intervention delivery
Study design | RCTs with n ≥50. The sample size requirement is designed to exclude small pilot studies that typically are underpowered and have more methodological problems than larger trials. Studies with small samples and no treatment effect are also less likely to be published, increasing the risk of publication bias. | RCTs with n <50
Publications | English-language publication Published from 2000 to present^*^ Peer-reviewed, full publication Study conducted in North America, the European Union, or Australia/New Zealand^†^ | Non-English language Published before 2000 Abstract only

* Rationale is that the Internet was developed in the 1990s and not used routinely for interventions until 2000. Based on our assessment of studies included in existing systematic reviews, the earliest relevant publication was in 2004.

† Rationale is to include economically developed countries with sufficient similarities in healthcare system and culture to be applicable to U.S. medical care.

Abbreviations: AUD=alcohol use disorder; CD-ROM=compact disc read-only memory; HRQOL=health-related quality of life; IVR=interactive voice response; KQ=key question; n=number of participants; RCTs=randomized controlled trials

## DATA ABSTRACTION

Before general use, the abstraction form templates, designed specifically for this report, were piloted on a sample of included articles and revised to ensure that all relevant data elements were captured and that there was consistency and reproducibility between abstractors. Data elements included descriptors to assess applicability, quality elements, intervention/exposure details, and outcomes. Key data elements abstracted included patient descriptors (including age, education, baseline alcohol use); setting, features and dose of the e-intervention, characteristics of the comparator, and outcomes as described in Table 2. Key features relevant to applicability included the match between the sample and target populations (eg, age, education level) and the training and experience of the clinician. Data from published reports were then abstracted into the final abstraction form by a trained investigator. All data abstractions were confirmed by a second investigator. Disagreements were resolved by consensus or by obtaining a third investigator's opinion. When data from published reports were missing or incomplete, we contacted study authors to request the data.

We abstracted the following key information for each included study:

- Study characteristics and design
  ○ Study identifiers—Author last name, year published, ID number
  ○ Study design—RCT, patient level or group level
  ○ Location (country) and recruitment setting (clinic, etc) of study
  ○ Number of study arms; types of comparison groups
  ○ Inclusion and exclusion criteria (identified by screen only or diagnostic criteria, etc)
  ○ Recruitment (eg, internet, advertisement); source (eg, campus, clinic)
  ○ Number of participants eligible for, randomized, enrolled in, and completing study
  ○ Analysis method for alcohol consumption: analysis of covariance (ANCOVA), mixed model, other
  ○ Did analysis account for missing data? (ie, mixed models or multiple imputation)
- Population characteristics
  ○ Sex, race, and age of sample
  ○ Inclusion of active duty or Veteran participants
  ○ Alcohol consumption at baseline (eg, drinks/week)
  ○ Are there important differences in alcohol diagnosis or severity (amount of consumption)?
- Description of the intervention and comparator
  ○ Comparator used (eg, waitlist, treatment as usual, informational or attention control, face-to-face treatment)
  ○ Comparator delivery, if applicable
  ○ Overall e-intervention classification (degree of support provided)
  ○ Type, delivery mode, and location of computer platform
  ○ “Brand” name of intervention
  ○ Theoretical basis of intervention (cognitive-behavioral therapy, motivational interviewing, etc)
  ○ Components of intervention
    ○ Group or individual
    ○ Number of sessions and minutes per session
    ○ Types of interactivity (eg, email, text messaging, telephone, peer component)
    ○ Techniques used (eg, personalized normative feedback [PNF], psychoeducation, negative consequences, tailored materials, etc)
  ○ Therapist credentials, level of therapist support (feedback, email, phone, etc)
  ○ Technical support, if offered
- Outcomes
  ○ Time points measured (number of follow-up assessments)
  ○ Study duration (longest follow-up, in weeks)
  ○ Treatment adherence: mean sessions completed or proportion completing all sessions
  ○ Patient satisfaction
  ○ Alcohol consumption (measured at time points closest to 6 and 12 months)
    ○ Standard drinks per week (and number of grams of alcohol per drink, if given)
    ○ Heavy drinking episodes (and definition of qualifying episode)
    ○ Achieved recommended drinking limits
  ○ Health outcomes
    ○ HRQOL
    ○ Alcohol-related accidents
    ○ Alcohol-related medical problems
    ○ Mortality
  ○ Utilization outcomes
    ○ Hospitalizations
    ○ Emergency department visits
  ○ Social or legal problems

## QUALITY ASSESSMENT

We abstracted data necessary to assess the quality (risk of bias) of included trials. Across all included trials, quality criteria were applied for each RCT by 2 independent investigators. Disagreements were resolved between the 2 investigators or, when needed, by arbitration from a third investigator. We used the key risk of bias criteria described in the Agency for Healthcare Research and Quality's (AHRQ's) Methods Guide for Effectiveness and Comparative Effectiveness Reviews,32 adapted to this specific topic and customized to RCTs (Appendix B). These criteria are: adequacy of randomization and allocation concealment; comparability of groups at baseline; blinding; completeness of follow-up and differential loss to follow-up; whether incomplete data were addressed appropriately; validity of outcome measures; and conflict of interest. We assigned a summary risk of bias score (low, moderate, or high) to individual studies. Detailed quality ratings for each included study are provided in Appendix C.

## DATA SYNTHESIS

While synthesizing relevant abstracted data, we developed a summary table describing the key outcomes used to test e-interventions in included RCTs. As part of this process, we classified the e-interventions according to the level of supplementary human support provided as follows:

- Level 1 (minimal): No support; e-intervention only
- Level 2 (low): Some support; e-intervention supplemented by non-counseling meetings with study staff
- Level 3 (moderate to high): Therapeutic support; e-intervention supplemented by counseling with trained staff

We grouped studies into those with eligibility criteria designed to enroll participants with alcohol misuse and those designed to enroll participants at high risk of or with AUD (ie, DSM-5 criteria or high threshold on screening test). Controls were grouped into inactive (waitlist, attention/information, and treatment as usual) and face-to-face active controls.

We then determined the feasibility of completing a quantitative synthesis (meta-analysis) to estimate summary effects. Feasibility depends on the volume of relevant literature, conceptual homogeneity of the trials, and completeness of results reporting. Because of important differences in the study samples and intervention designs, we planned a priori to analyze studies conducted in college samples separately from studies conducted in other adult samples.

When meta-analysis was feasible, we computed summary estimates of effect, stratified by condition (alcohol misuse versus at risk of AUD or with AUD), for both end-of-treatment and longest follow-up point ≥6 months. When trials evaluated more than one e-intervention, we averaged the effect across e-interventions.33-36 Meta-analyses were feasible only for the e-interventions compared with inactive controls. Because the primary outcome—alcohol consumption—was measured across the trials using different units, the measurements were converted to a common unit (grams/week) and were combined using mean differences (MDs).37,38 If means and standard deviations (SDs) were not reported, we used other statistics (eg, median, F values) to calculate effect sizes. Because of the relatively small number of studies, we used a random-effects model with the Knapp and Hartung method to adjust the standard errors of the estimated coefficients.39,40 The dichotomous outcome “met drinking limits” was analyzed using summary risk ratios (RRs). For outcomes that used different measures to evaluate the construct (eg, social or legal problems from alcohol misuse), we computed summary estimates using standardized mean differences (SMDs). At each time point, the SMD was calculated by subtracting the average intake of the intervention group from the average intake of the control group and dividing the result by the pooled standard deviations of the 2 groups. SMDs of 0.2 can be considered small treatment effects; 0.5, moderate effects; and ≥0.8, large effects.41 We evaluated for statistical heterogeneity in treatment effects using Cochran's Q and I^2^ statistics. An I^2^ of 0% indicates no observed heterogeneity, and larger values suggest increasing heterogeneity: 25% is interpreted as low, 50% as moderate, and ≥75% as high heterogeneity.42

We planned subgroup analyses to explore potential sources of heterogeneity, specifying a priori: follow-up rates, treatment dose, and the level of support given with the intervention. Consistent with AHRQ's Methods Guide, we specified a minimum of 4 studies per subgroup to conduct the planned analyses.43 However, because of the relatively small number of studies and lack of variability in moderator variables, subgroup analyses were not performed. When there were at least 3 studies at low or moderate risk of bias, we performed sensitivity analyses to compute summary estimates after excluding studies at high risk of bias.

We used R (R Foundation for Statistical Computing, Vienna, Austria) with the metafor package44 to calculate the summary estimates of treatment effect. Publication bias was assessed using findings from a search of ClinicalTrials.gov Funnel plots were not used because analyses did not meet the minimum threshold of at least 10 studies for meaningful analysis.32

Where quantitative synthesis was not feasible, we analyzed the data qualitatively. We gave more weight to the evidence from higher quality studies with more precise estimates of effect. A precise estimate of effect was defined as one that excluded a difference of ≤3 standard drinks per week or a SMD of ≤0.4. The qualitative syntheses focused on documenting and identifying patterns in efficacy and safety of the interventions across conditions and outcome categories. We also analyzed potential reasons for inconsistency in treatment effects across studies by evaluating differences in the study population, intervention, comparator, and outcome definitions.

## RATING THE BODY OF EVIDENCE

In addition to rating the quality of individual studies, we evaluated the overall strength of evidence (SOE) for each KQ as described in AHRQ's Methods Guide for Effectiveness and Comparative Effectiveness Reviews.32 In brief, this approach requires assessment of 4 domains: risk of bias, consistency, directness, and precision. These domains, along with evidence for publication bias, were considered qualitatively, and a summary rating of high, moderate, low, or insufficient SOE was assigned after discussion by 2 investigators. The 4-level rating scale consists of the following definitions:

- High—We are very confident that the true effect lies close to the estimate of the effect.
- Moderate—We are moderately confident in the effect estimate: The true effect is likely to be close to the estimate of the effect, but there is a possibility that it is substantially different.
- Low—Our confidence in the effect estimate is limited: The true effect may be substantially different from the estimate of the effect.
- Insufficient—Evidence on an outcome is absent or too weak, sparse, or inconsistent to estimate an effect.

When a rating of high, moderate, or low was not possible or was imprudent to make, a rating of insufficient was assigned.

## PEER REVIEW

A draft of this report was reviewed by technical experts and clinical leadership. A transcript of their comments and our responses is provided in Appendix D.