# INTRODUCTION

The economic, social, and health burden of alcohol misuse is widely recognized,1 as is the need for effective interventions to reduce this burden.2,3 Alcohol misuse constitutes the third leading cause of morbidity and mortality worldwide4-6 and is the third leading cause of preventable death in the United States, after tobacco use and obesity.7,8 Alcohol misuse contributes to a multitude of medical and psychiatric illnesses and presents across all medical specialties. The associated costs amount to more than 1% of the gross national product in high- and middle-income countries.6,9 Veterans, who account for approximately 21.8 million people in the United States,10 are among those significantly affected by addiction.11 Substance use disorders, including alcohol use disorder (AUD), are among the most common and costly conditions among Veterans presenting for treatment in the Veterans Health Administration (VHA) system.12,13 Among Veterans with at least one primary care visit in VHA within the past year, 589,094 (14.5%) screened positive for alcohol misuse, and 396,374 had a diagnosis of AUD with or without another substance use disorder (Daniel Kivlahan, PhD, e-mail communication, July 2014).

Studies on alcohol misuse conceptualize the target problem differently, and the recently introduced Diagnostic and Statistical Manual of Mental Disorders, 5th edition (DSM-5),14 criteria include important revisions to the nosology. The key change for DSM-5 was to integrate “alcohol abuse” and “alcohol dependence” diagnoses into a single disorder, “alcohol use disorder” (AUD), with mild, moderate, and severe subclassifications. To provide clarity on the use of terminology for alcohol consumption patterns and related problems, Table 1 provides operational definitions for the terms used in this report.

Table 1 Definitions of the Spectrum of Alcohol Misuse^*^

Term | Definition (Reference Time Period: 1 Year)
Risky Use or Hazardous Use | Excess daily consumption (>4 drinks/day in men, >3 drinks/day in women and men over age 65) or excess total consumption (>14 drinks/week in men, >7 drinks/week in women and men over age 65) associated with increased risk of health problems.
Harmful use | A pattern of drinking that is already causing damage to health. The damage may be either physical (eg, liver damage) or mental (eg, depressive episodes).
Alcohol abuse (DSM-IV criteria)^†^ | A maladaptive pattern of alcohol use leading to clinically significant impairment or distress (eg, failure to fulfill major obligations). Continued use despite persistent or recurrent social or interpersonal problems caused or exacerbated by alcohol.
Alcohol dependence (DSM-IV criteria)^†^ | A maladaptive pattern of alcohol use leading to clinically significant impairment or distress, which may include symptoms associated with alcoholism or addiction: tolerance, withdrawal, excessive amounts consumed or time spent drinking, unsuccessful attempts to decrease use, pattern continues despite persistent problems caused by or associated with alcohol.
Alcohol use disorder (AUD) (DSM-5 criteria)^†^ | This new category integrates the 2 DSM-IV disorders “alcohol abuse” and “alcohol dependence” into a single disorder for DSM-5: An individual continues pattern of alcohol use despite significant substance-related problems in one or more of the following areas: impaired control over use (eg, inability to decrease consumption), social impairment (eg, failing an obligation or foregoing a favorite activity), health consequences (physical or mental), and physiological dependence (eg, cravings). The disorder is classified as mild, moderate, or severe depending on number of symptoms.

* The term “alcohol misuse” (sometimes termed “unhealthy alcohol use”) is an umbrella term for a spectrum of potentially problematic patterns of alcohol use. This table is adapted with permission from Table 1 in Jonas et al, 2012,8 and uses terminology from the DSM-IV15 for alcohol abuse and alcohol dependence, and from the DSM-5^14^ for AUD. The source table was abbreviated and updated to reflect the DSM-5 terminology for this report in collaboration with Dr. Jonas.

† Not all exact criteria are listed.

Abbreviations: AUD=alcohol use disorder; DSM-5=Diagnostic and Statistical Manual of Mental Disorders, 5th edition; DSM-IV=Diagnostic and Statistical Manual of Mental Disorders, 4th edition

Traditional treatment approaches for AUD, which usually consist of initial intensive and time-limited interventions followed by less intensive follow-up care,12 can be prohibitive for individuals seeking treatment for a variety of reasons. Even the use of screening and brief interventions for less severe alcohol misuse, which have been shown to be effective, are constrained by barriers such as adequate funding, time, and adequately trained personnel.16-18 Thus, electronic interventions (e-interventions) may prove to be a useful way to extend the reach of interventions for alcohol misuse. With 87% of the U.S. population using the Internet,19 e-interventions have the potential to reach individuals with drinking problems who wish to remain anonymous, have little time for traditional therapy, need therapy to be available during non-standard business hours due to shift work, live at great distance from traditional therapy, or cannot afford such therapy.20,21 Given that Veterans can encounter most, if not all, of the barriers to accessing care for alcohol misuse, e-interventions may prove a promising avenue, especially for the younger, more Internet-savvy Veterans returning from recent deployments in places such as Iraq and Afghanistan.

Prior reviews focus on student or young adult populations,22-24 do not include the most recent trials,21,25,26 include studies with only short-term outcomes27 or studies restricted to web-based interventions,22,25 or combine alcohol and other substance use in the same analyses.28 To inform policy for VHA, we focused on studies that reported longer term, clinically important outcomes and evaluated effects separately for student and non-student populations. We offer a systematic review of randomized controlled trials (RCTs) assessing CD-ROM-based, web-based, interactive voice response (IVR), or mobile applications of e-interventions for alcohol misuse in order to assess for changes in alcohol consumption, alcohol-related health problems, alcohol-related social or legal problems, health-related quality of life (HRQOL), functional status, medical utilization, and adverse effects. We intend the evidence synthesis to be used to inform the decision whether to disseminate e-interventions for alcohol misuse in VHA, and how best to implement programs.