# E-INTERVENTION CHARACTERISTICS

Study | Population | e-Intv | Support Level | Computer Type | Computer Location | Security/PHI? | e-Program Name | GS-PNF? Comparison | Treatment Technique | Face-to-face in e-Intv? | Live Therapy Sessions? | Computer Sessions (Number, Length)
Barnett, 2007^1^ | Students | e-Intv | 2 | Software program on a PC (desk or laptop) | NR | NR | Alcohol 101 | Yes; student peers | PsyEdu, AEdu | Yes, for intake only; F2F control | 1 × 45 min individual session; 2^nd^, 25 min session 1 mo later in half of each arm if randomized to booster | 1 × 20-25 min; 2^nd^ × 20-25 min if randomized to booster
Bischof, 2008^2^ | Adults | e-Intv + phone (full, stepped) | 3 | NR | NR | NR | NR | No | SBI, TF | Yes, with the e-Intv | 4 scheduled calls, each 30-40 min | 1, length NR
Boon, 2011^3^ | Adults | e-Intv | 2 | Accessed via Web | University | NR | www.drinktest.nl | Yes; age-matched adults | SBI, NC, goals | RA for screening only | NA | 1 × 10 min
Cucciare, 2013^4^ | Adults | e-Intv | 1 | Accessed via Web | PC in clinic | NR | NR | Yes; age-matched adults | PsyEdu, NC | No | NA | 1 × 10-15 min
Cunning-ham, 2009^5^ | Adults | e-Intv | 1 | Accessed via Web | NR | Secure; no PHI | Check Your Drinking | Yes: age-matched adults | PsyEdu, NC, SBI | No | NA | 1 × <10 min
Gustafson, 2014^6^ | Adults | e-Intv after residential treatment | 2 | Smartphone | Mobile | Secure; NR | A-CHESS | No | AS-Edu, CBT, email, GPS, peer, RP, S-M, text | No | No | 41% used some features daily; weekly check-in
Hansen, 2012^7^ | Adults | e-Intv PFI & PNF | 1 | Accessed via Web | NR | Secure; NR | NR | Yes; municipality residents | SBI, NC, PsyEdu | No | NA | 1, length NR
Hasin, 2013^8^ | Adult-HIV patents | IVR+MI | 3 | NA: IVR | NA | NR | NR | NA (IVR) | PsyEdu, SBI, S-M, goals | Yes, MI with PhD; F2F control | 3 in-person sessions 1st: 20-25 min; 2nd/3rd: 10-15 min | IVR, 60 days, 1-3 min per day
Helzer, 2008^9^ | Adults | IVR | 3 | NA: IVR (PCP-BI+IVR; PCP-BI+IVR+PNF) | IVR on phone | NR | NR | NA (IVR) | SBI, S-M, goals | Yes, for intake only; F2F control | NR | Daily IVR × 6 mo; Monthly group; length NR
Hester, 2012^10^ | Students | e-Intv | 2 | Software program on a PC (desktop or laptop) | Student health clinic | Secure; no PHI | College Drinker's Checkup | Yes; student peers | SBI, NC, goals, DBE | RA for screening only | NA | 1 × 35 min
Kypri, 2009^11^ | Students | e-Intv | 1 | Accessed via Web | Home | NR | THRIVE | Yes: age-matched, New Zealand population | PsyEdu, NC, Hwk, TF | No | (Extensive assessment) | 2 (1 + “booster” at 1 mo); length NR
Kypri, 2008^12^ | Students | e-Intv × 1 (multi-dose × 3) | 2 | Accessed via Web | NR | NR | NR | NR | SBI, AS-Edu | RA for screening only | NA | 1 or 3 SBI sessions; median length 9.3 min
Kypri, 2004^13^ | Students | e-Intv | 2 | Accessed via Web | Student Health Clinic | NR | NR | NR | SBI, NC, AS-Edu, CMN | RA for screening only | Technical aid plus gave leaflet | 1, average length 11.2 min
Monahan, 2013a14 | Students | e-Intv | 1 | Software program on a PC (desktop or laptop) | Research lab | NR | Alcohol 101 | No | PsyEdu | Yes, graduate student for intake; F2F control | 1 individual session, 50-60 min | 1 × 30+ min
Monahan, 2013b14 | Students | e-Intv | 1 | Software program on a PC (desktop or laptop) | Research lab | NR | e-CHUG | Yes; student peers | PsyEdu | Yes, graduate student for intake; F2F control | 1 individual session, 50-60 min | 1 × 30+ min
Moreira, 2012^15^ | Students | e-Intv | 1 | Accessed via Web | NR | NR | NR | Yes, but not GS; student peers | SBI, AS-Edu | No | NA | 1, length NR
Mundt, 2006^16^ | Adults: Relapse prevention | IVR IVR + FU | 3 | NA: IVR | NA | Secure; no PHI | NR | NA (IVR) | PsyEdu, SBI, S-M, goals | Yes, with study coordinator | 4 calls; option to receive and/or leave phone messages | IVR, 90 days, <5 min each day
Neighbors, 2010^17^ | Students | e-Intv GSF, GSF2+ | 1 | Accessed via Web | NR | Secure; NR | BASICS | Yes: student peers | SBI | No | NA | GSF: 1 GSF2+: 2-5 based on adherence (each 50 min long)
Neighbors, 2004^18^ | Students | e-Intv | 1 | Accessed via Web | College classroom | NR | BASICS | Yes, but NR if GS; student peers | PsyEdu, SBI | No | NA but extensive assessment | 1, length NR
Neumann, 2006^19^ | Adults | e-Intv | 2 | Software program on a PC (desk or laptop) | Clinic | NR | FRAMES | Yes, but GS NA (all men) | PsyEdu, SBI, goals, TPR | RA for screening only | NA | 1 × 90 min
Riper, 2008^20^ | Adults | e-Intv | 2 | Accessed via Web | NR | Secure; no PHI | minderdrinken.nl | No | S-M, ST, goals | Moderated peer-to-peer discussion forum | 6 wk | NR
Schulz 2013^21^ | Adults | e-Intv | 1 | Accessed via Web | NA | NR | Alcohol-Everything Within Limits | Yes, but NR if GS; NR | AS-Edu, NC, PNF, PsyEdu, TF | No | No | 3, length NR
Sinadinovic, 2012^22^ | Adults: alcohol &drug | e-Intv | 1 | Accessed via Web | NR | NR | eScreen.se | Yes, but NR if GS; Swedish population | SBI, S-M, MI | No | NA | Unlimited; mean (SD) = 2.66 (4.31), length NR
Voogt, 2013^23^ | Students | e-Intv | 1 | Accessed via Web | NR | NR | What Do You Drink (WDYD) | Yes; student peers | PsyEdu | No | NA | 1 × 20 min
Wallace, 2011^24^ | Adults | e-Intv | 1 | Accessed via Web | NR | Secure; no PHI | Down Your Drink | Yes; UK population | SBI, S-M, ST, goals, VC, RP | No | NA | Unlimited, length NR
Walters, 2009^25^ | Students | e-Intv | 1 | Accessed via Web | Home | NR | e-CHUG (modified) | Yes: U.S. student norms | SBI, NC | No; F2F control | NA | 1 × 30 min

Abbreviations: A-CHESS=Addiction-Comprehensive Health Enhancement Support System; AEdu=alcohol education through “virtual party,” taking personal responsibility; AS-Edu=alcohol-specific education; BASICS=Brief Alcohol Screening and Intervention for College Students; CBT=computerized cognitive-behavioral therapy program; CMN=correction of misperceived norms; DBE=decisional balance exercise; e-CHUG=Electronic Check-Up to Go; e-Intv=electronic intervention; email=email response from counselor; F2F=face-to-face; FRAMES=feedback, responsibility, advice, menu of options, empathy, self-efficacy; FU=follow-up; goals=goal-setting; GPS=global position monitoring of high-risk locations; GS=gender-specific; GSF=gender-specific feedback; GSF2+=multi-dose gender-specific feedback; GS-PNF=gender-specific personalized normative feedback; HIV=human immunodeficiency virus; Hwk=homework; IVR= interactive voice response; MI=motivational interviewing; min=minute(s); mo=month(s); NA=not applicable; NC=negative consequences; NR=not reported; PC=personal computer; PCP-BI=brief intervention from primary care physician; peer=online peer support; PFI=personalized feedback intervention; PHI=protected health information; PNF=personalized normative feedback; PsyEdu=psychoeducation; RA=research assistant; RP=relapse prevention; SBI=screening and brief intervention; SD=standard deviation; S-M=self-monitoring; ST=skills training; text=motivational quotes via text message; TF=tailored feedback (blood level); THRIVE=Tertiary Health Research Intervention Via Email; TPR=taking personal responsibility; VC=values clarification; WDYD=What Do You Drink; wk=weeks

## References to Appendix F

1 Barnett NP, Murphy JG, Colby SM, Monti PM. Efficacy of counselor vs. computer-delivered intervention with mandated college students. Addict Behav. 2007;32(11):2529-2548. [pmid: 17707594].
2 Bischof G, Grothues JM, Reinhardt S, Meyer C, John U, Rumpf HJ. Evaluation of a telephone-based stepped care intervention for alcohol-related disorders: a randomized controlled trial. Drug Alcohol Depend. 2008;93(3):244-251. [pmid: 18054443].
3 Boon B, Risselada A, Huiberts A, Riper H, Smit F. Curbing alcohol use in male adults through computer generated personalized advice: randomized controlled trial. J Med Internet Res. 2011;13(2):e43. [pmid: 21719412].
4 Cucciare MA, Weingardt KR, Ghaus S, Boden MT, Frayne SM. A randomized controlled trial of a web-delivered brief alcohol intervention in Veterans Affairs primary care. J Stud Alcohol Drugs. 2013;74(3):428-436. [pmid: 23490572].
5 Cunningham JA, Wild TC, Cordingley J, van Mierlo T, Humphreys K. A randomized controlled trial of an internet-based intervention for alcohol abusers. Addiction. 2009;104(12):2023-2032. [pmid: 19922569].
6 Gustafson DH, McTavish FM, Chih MY, et al. A smartphone application to support recovery from alcoholism: a randomized clinical trial. JAMA Psychiatry. 2014;71(5):566-572. [pmid: 24671165].
7 Hansen AB, Becker U, Nielsen AS, Gronbaek M, Tolstrup JS, Thygesen LC. Internet-based brief personalized feedback intervention in a non-treatment-seeking population of adult heavy drinkers: a randomized controlled trial. J Med Internet Res. 2012;14(4):e98. [pmid: 22846542].
8 Hasin DS, Aharonovich E, O'Leary A, et al. Reducing heavy drinking in HIV primary care: a randomized trial of brief intervention, with and without technological enhancement. Addiction. 2013;108(7):1230-1240. [pmid: 23432593].
9 Helzer JE, Rose GL, Badger GJ, et al. Using interactive voice response to enhance brief alcohol intervention in primary care settings. J Stud Alcohol Drugs. 2008;69(2):251-258. [pmid: 18299766].
10 Hester RK, Delaney HD, Campbell W. The college drinker's check-up: outcomes of two randomized clinical trials of a computer-delivered intervention. Psychol Addict Behav. 2012;26(1):1-12. [pmid: 21823769].
11 Kypri K, Hallett J, Howat P, et al. Randomized controlled trial of proactive web-based alcohol screening and brief intervention for university students. Arch Intern Med. 2009;169(16):1508-1514. [pmid: 19752409].
12 Kypri K, Langley JD, Saunders JB, Cashell-Smith ML, Herbison P. Randomized controlled trial of web-based alcohol screening and brief intervention in primary care. Arch Intern Med. 2008;168(5):530-536. [pmid: 18332300].
13 Kypri K, Saunders JB, Williams SM, et al. Web-based screening and brief intervention for hazardous drinking: a double-blind randomized controlled trial. Addiction. 2004;99(11):1410-1417. [pmid: 15500594].
14 Monahan CJ, McDevitt-Murphy ME, Dennhardt AA, Skidmore JR, Martens MP, Murphy JG. The impact of elevated posttraumatic stress on the efficacy of brief alcohol interventions for heavy drinking college students. Addict Behav. 2013;38(3):1719-1725. [pmid: 23261489].
15 Moreira MT, Oskrochi R, Foxcroft DR. Personalised normative feedback for preventing alcohol misuse in university students: Solomon three-group randomised controlled trial. PLoS One. 2012;7(9):e44120. [pmid: 22984466].
16 Mundt JC, Moore HK, Bean P. An interactive voice response program to reduce drinking relapse: a feasibility study. J Subst Abuse Treat. 2006;30(1):21-29. [pmid: 16377449].
17 Neighbors C, Lewis MA, Atkins DC, et al. Efficacy of web-based personalized normative feedback: a two-year randomized controlled trial. J Consult Clin Psychol. 2010;78(6):898-911. [pmid: 20873892].
18 Neighbors C, Larimer ME, Lewis MA. Targeting misperceptions of descriptive drinking norms: efficacy of a computer-delivered personalized normative feedback intervention. J Consult Clin Psychol. 2004;72(3):434-447. [pmid: 15279527].
19 Neumann T, Neuner B, Weiss-Gerlach E, et al. The effect of computerized tailored brief advice on at-risk drinking in subcritically injured trauma patients. J Trauma. 2006;61(4):805-814. [pmid: 17033544].
20 Riper H, Kramer J, Smit F, Conijn B, Schippers G, Cuijpers P. Web-based self-help for problem drinkers: a pragmatic randomized trial. Addiction. 2008;103(2):218-227. [pmid: 18199300].
21 Schulz DN, Candel MJ, Kremers SP, Reinwand DA, Jander A, de Vries H. Effects of a Web-based tailored intervention to reduce alcohol consumption in adults: randomized controlled trial. J Med Internet Res. 2013;15(9):e206. [pmid: 24045005].
22 Sinadinovic K, Wennberg P, Berman AH. Targeting problematic users of illicit drugs with Internet-based screening and brief intervention: a randomized controlled trial. Drug Alcohol Depend. 2012;126(1-2):42-50. [pmid: 22613182].
23 Voogt CV, Poelen EA, Kleinjan M, Lemmers LA, Engels RC. The effectiveness of the ‘what do you drink’ web-based brief alcohol intervention in reducing heavy drinking among students: a two-arm parallel group randomized controlled trial. Alcohol Alcohol. 2013;48(3):312-321. [pmid: 23303466].
24 Wallace P, Murray E, McCambridge J, et al. On-line randomized controlled trial of an internet based psychologically enhanced intervention for people with hazardous alcohol consumption. PLoS One. 2011;6(3):e14740. [pmid: 21408060].
25 Walters ST, Vader AM, Harris TR, Field CA, Jouriles EN. Dismantling motivational interviewing and feedback for college drinkers: a randomized clinical trial. J Consult Clin Psychol. 2009;77(1):64-73. [pmid: 19170454].