# STUDY CHARACTERISTICS

Study; No. of participants randomized; No. of treatment arms | Intervention Type | Control Type | Age (Mean [SD]); % Female; % White | Location; Setting; VA? (Yes/No) | Education (by Category or Mean Years [SD]) | Baseline Alcohol Intake (g/wk) | Baseline Alcohol Score (Instrument)
Barnett, 2007^1^ 225 2 | Electronic intervention (e-Intv) | Face-to-face | 18.8 (0.9) 51 76 | USA University No | Total population: ≥college: 100% | 92.15 | NR
Bischof, 2008^2^ 408 3 | e-Intv + phone (full) e-Intv + phone (stepped) | Waitlist (WL) | 36.5 (13.5) 32 NR | Europe NR No | Mean years(SD): e-Intv (full): 10.3 (2.7) e-Intv (stepped): 10.4 (2.7) WL: 10.4(2.1) | 253.90 | NR
Boon, 2011^3^ 450 2 | e-Intv | Information control (IC) | 40.5 (15.2) 0 NR | Europe Web access No | e-Intv: <college: 46.1% ≥college: 53.9% IC: <college: 47.7% ≥college: 52.3% | 312.91 | NR
Cucciare, 2013^4^ 167 2 | e-Intv | Treatment as usual (TAU) | 59.3 (15.0) 12 69 | USA Clinic Yes | NR | 336.11 | AUDIT-C Overall: 6.4 (2.50) e-Intv : 6.3 (2.5) TAU :6.5 (2.5)
Cunningham, 2009^5^ 185 2 | e-Intv | IC | 40.20 (13.45) 47 NR | Canada NR No | e-Intv: ≥college: 78.3% IC: ≥college: 77.4% | 180.52 | AUDIT-C Overall: 6.7 (2.10) e-Intv : 7.0 (2.1) IC: 6.4 (2.1)
Gustafson, 2014^6^ 349 2 | e-Intv + TAU | TAU | 38.0 (10.0) 39.3 80.2 | USA Smartphone No | Total population: <college: 92.0% ≥college: 8.0% | NR | NR
Hansen, 2012^7^ 1380 3 | e-Intv (PNF) e-Intv (personalized brief advice) | WL | 44-65 (range) 45 NR | Europe Web access No | Total population: 15+ years of education: 51.7% | 271.87 | NR
Hasin, 2013^8^ 258 3 | Motivational interviewing (MI) + interactive voice response (IVR) | MI IC | 45.70 (8.10) 22 None (100% African-American) | USA NR (primary diagnosis is HIV) No | NR | NR | NR
Helzer, 2008^9^ 273 3 | Brief intervention from primary care physician (PCP-BI) + IVR PCP-BI + IVR + PNF | PCP-BI | 45.10 (12.00) 38 NR | Europe NR (IVR study) No | Mean (SD): years PCP-BI + IVR: 14.8 (3.1) PCP-BI + IVR + PNF: 15.0 (2.7) PCP-BI (control): 14.9 (2.8) | 430.48 | NR
Hester, 2012^10^ 144 2 | e-Intv | TAU | 20.40 (2.0) 38 57 | USA University clinic No | Total population: ≥college: 100% | 290.75 | NR
Kypri, 2009^11^ 2435 2 | e-Intv | WL | 19.70 (2.0) 45 NR | New Zealand Web access No | e-Intv: ≥college: 100% WL: ≥college: 100% | 85.00 | Instrument NR Overall: 14.2 (5.10) e-Intv : 14.2 (5.1) WL: 14.3 (5.1)
Kypri, 2008^12^ 429 2 | e-Intv | IC | 20.1 (2.00) 52 NR | New Zealand NR No | e-Intv: ≥college: 100% IC: ≥college: 100% | NR | AUDIT Overall: 14.9 (5.10) e-Intv: 14.9 (5.1) IC: 15.1 (5.5)
Kypri, 2004^13^ 104 2 | e-Intv | IC | 20.20 (1.62) NR NR | New Zealand University clinic No | e-Intv: ≥college: 100% IC: ≥college: 100% | NR | AUDIT Overall: 16.6 (5.85) e-Intv: 16.6 (5.7) IC: 16.6 (6.0)
Monahan, 2013a14 74 2 | e-Intv (Alcohol 101) | MI (BASICS) | 18-26 (range) 59 73 | USA University research lab No | Total population: ≥college: 100% | 176.83 | NR
Monahan, 2013b14 133 3 | e-Intv (e-CHUG) | MI (BASICS) WL | 18-26 (range) 50 65.4 | USA University research lab No | Total population: ≥college: 100% | 205.18 | NR
Moreira, 2012^15^ 1751 2 | e-Intv | WL | 17-19: 59.6% 20-24: 34.3% >25: 6.1% OR <25: 93.7% 62 NR | Europe NR No | Total population: ≥college: 100% | 140.61 | AUDIT Overall: 11.10 (7.01) e-Intv : 11.25 (7.15) WL: 11 (6.86)
Mundt, 2006^16^ 60 3 | IVR IVR + follow-up For relapse prevention | WL | 41.9 (9.20) 45 95 | USA NR (IVR) No | NR | NA (relapse prevention) | NR
Neighbors, 2010^17^ 491 3 | e-Intv (gender-specific feedback [GSF]) multi-dose (GSF2+) | Attention control (AC) | 18.2 (0.60) 57.6 65.3 | USA NR No | Total population: ≥college: 100% | 159.12 | NR
Neighbors, 2004^18^ 252 2 | e-Intv | WL | 18.50 (1.2) 59 79.5 | USA University No | Total population: ≥college: 100% | 161.35 | ACI (alcohol consumption inventory) Overall: 1.95 (1.35) e-Intv:2.03 (1.35) WL: 1.86 (1.35)
Neumann, 2006^19^ 1136 2 | e-Intv | WL | Median (range): 30.5 (24-29) 21 NR | Europe Clinic No | NR | 188.91 | AUDIT (median [IQR]) e-Intv: 7 (6-11) WL: 8 (6-11)
Riper, 2008^20^ 261 2 | e-Intv | IC | 46.1 (9.1) 49 NR | Europe NR No | e-Intv: <college: 31.5% ≥college: 68.5% IC: <college: 29 ≥college: 71 | 436.00 | NR
Schulz, 2013^21^ 448 2 | e-Intv | WL | 41.72 (NR) 43.5 NR | Europe Web access No | Total population: ≥college: 34% | 129.4 | AUDIT≥ 8 Overall: 80%
Sinadinovic, 2012^22^ 202 2 | e-Intv | TAU | 32.5 (NR) 45 NR | Europe NR Dual diagnosis: ETOH + drug No | NR | NR | AUDIT-C Overall: 7.60 (2.85) e-Intv: 7.8 (2.7) TAU: 7.3 (3.0)
Voogt, 2013^23^ 913 2 | e-Intv | WL | 20.9 (1.70) 40 NR | Europe NR No | Total population: ≥college: 100% | 218.01 | NR
Wallace, 2011^24^ 2652 2 | e-Intv | IC | 38.0 (11.0) 57 NR | Europe NR No | e-Intv: ≥college: 52% IC: ≥college: 51% | 368.00 | AUDIT-C Overall: 8.5 (2.02)
Walters, 2009^25^ 279 4 | e-Intv (web FB only) | MI MI + FB WL | 19.80 (NR) 64.2 84.6 | USA University No | Total population: ≥college: 100% | 206.95 | Other RAPI alcohol-related problems Overall: 6.35 (6.45) e-Intv: 5.99 (6.01) MI: 6.37 (6.50) MI + FB: 6.67 (6.92) WL: 6.38 (6.35)

Abbreviations: AC=attention control; AUDIT=Alcohol Use Disorders Identification Test; AUDIT-C=Alcohol Use Disorders Identification Test-Consumption; e-Intv=electronic intervention; ETOH=alcohol; FB=feedback; g=grams; GSF=gender-specific feedback; GSF2+=multi-dose gender-specific feedback; HIV=human immunodeficiency virus; IC=information control; IQR=interquartile range; IVR= interactive voice response; MI=motivational interviewing; NA=not applicable; NR=not reported; PCP-BI=brief intervention from primary care physician; PNF=personalized normative feedback; RAPI=Rutgers Alcohol Problem Index; SD=standard deviation; TAU=treatment as usual; VA=Veterans Administration; wk=week; WL=waitlist

## References to Appendix E

1 Barnett NP, Murphy JG, Colby SM, Monti PM. Efficacy of counselor vs. computer-delivered intervention with mandated college students. Addict Behav. 2007;32(11):2529-2548. [pmid: 17707594].
2 Bischof G, Grothues JM, Reinhardt S, Meyer C, John U, Rumpf HJ. Evaluation of a telephone-based stepped care intervention for alcohol-related disorders: a randomized controlled trial. Drug Alcohol Depend. 2008;93(3):244-251. [pmid: 18054443].
3 Boon B, Risselada A, Huiberts A, Riper H, Smit F. Curbing alcohol use in male adults through computer generated personalized advice: randomized controlled trial. J Med Internet Res. 2011;13(2):e43. [pmid: 21719412].
4 Cucciare MA, Weingardt KR, Ghaus S, Boden MT, Frayne SM. A randomized controlled trial of a web-delivered brief alcohol intervention in Veterans Affairs primary care. J Stud Alcohol Drugs. 2013;74(3):428-436. [pmid: 23490572].
5 Cunningham JA, Wild TC, Cordingley J, van Mierlo T, Humphreys K. A randomized controlled trial of an internet-based intervention for alcohol abusers. Addiction. 2009;104(12):2023-2032. [pmid: 19922569].
6 Gustafson DH, McTavish FM, Chih MY, et al. A smartphone application to support recovery from alcoholism: a randomized clinical trial. JAMA Psychiatry. 2014;71(5):566-572. [pmid: 24671165].
7 Hansen AB, Becker U, Nielsen AS, Gronbaek M, Tolstrup JS, Thygesen LC. Internet-based brief personalized feedback intervention in a non-treatment-seeking population of adult heavy drinkers: a randomized controlled trial. J Med Internet Res. 2012;14(4):e98. [pmid: 22846542].
8 Hasin DS, Aharonovich E, O'Leary A, et al. Reducing heavy drinking in HIV primary care: a randomized trial of brief intervention, with and without technological enhancement. Addiction. 2013;108(7):1230-1240. [pmid: 23432593].
9 Helzer JE, Rose GL, Badger GJ, et al. Using interactive voice response to enhance brief alcohol intervention in primary care settings. J Stud Alcohol Drugs. 2008;69(2):251-258. [pmid: 18299766].
10 Hester RK, Delaney HD, Campbell W. The college drinker's check-up: outcomes of two randomized clinical trials of a computer-delivered intervention. Psychol Addict Behav. 2012;26(1):1-12. [pmid: 21823769].
11 Kypri K, Hallett J, Howat P, et al. Randomized controlled trial of proactive web-based alcohol screening and brief intervention for university students. Arch Intern Med. 2009;169(16):1508-1514. [pmid: 19752409].
12 Kypri K, Langley JD, Saunders JB, Cashell-Smith ML, Herbison P. Randomized controlled trial of web-based alcohol screening and brief intervention in primary care. Arch Intern Med. 2008;168(5):530-536. [pmid: 18332300].
13 Kypri K, Saunders JB, Williams SM, et al. Web-based screening and brief intervention for hazardous drinking: a double-blind randomized controlled trial. Addiction. 2004;99(11):1410-1417. [pmid: 15500594].
14 Monahan CJ, McDevitt-Murphy ME, Dennhardt AA, Skidmore JR, Martens MP, Murphy JG. The impact of elevated posttraumatic stress on the efficacy of brief alcohol interventions for heavy drinking college students. Addict Behav. 2013;38(3):1719-1725. [pmid: 23261489].
15 Moreira MT, Oskrochi R, Foxcroft DR. Personalised normative feedback for preventing alcohol misuse in university students: Solomon three-group randomised controlled trial. PLoS One. 2012;7(9):e44120. [pmid: 22984466].
16 Mundt JC, Moore HK, Bean P. An interactive voice response program to reduce drinking relapse: a feasibility study. J Subst Abuse Treat. 2006;30(1):21-29. [pmid: 16377449].
17 Neighbors C, Lewis MA, Atkins DC, et al. Efficacy of web-based personalized normative feedback: a two-year randomized controlled trial. J Consult Clin Psychol. 2010;78(6):898-911. [pmid: 20873892].
18 Neighbors C, Larimer ME, Lewis MA. Targeting misperceptions of descriptive drinking norms: efficacy of a computer-delivered personalized normative feedback intervention. J Consult Clin Psychol. 2004;72(3):434-447. [pmid: 15279527].
19 Neumann T, Neuner B, Weiss-Gerlach E, et al. The effect of computerized tailored brief advice on at-risk drinking in subcritically injured trauma patients. J Trauma. 2006;61(4):805-814. [pmid: 17033544].
20 Riper H, Kramer J, Smit F, Conijn B, Schippers G, Cuijpers P. Web-based self-help for problem drinkers: a pragmatic randomized trial. Addiction. 2008;103(2):218-227. [pmid: 18199300].
21 Schulz DN, Candel MJ, Kremers SP, Reinwand DA, Jander A, de Vries H. Effects of a Web-based tailored intervention to reduce alcohol consumption in adults: randomized controlled trial. J Med Internet Res. 2013;15(9):e206. [pmid: 24045005].
22 Sinadinovic K, Wennberg P, Berman AH. Targeting problematic users of illicit drugs with Internet-based screening and brief intervention: a randomized controlled trial. Drug Alcohol Depend. 2012;126(1-2):42-50. [pmid: 22613182].
23 Voogt CV, Poelen EA, Kleinjan M, Lemmers LA, Engels RC. The effectiveness of the ‘what do you drink’ web-based brief alcohol intervention in reducing heavy drinking among students: a two-arm parallel group randomized controlled trial. Alcohol Alcohol. 2013;48(3):312-321. [pmid: 23303466].
24 Wallace P, Murray E, McCambridge J, et al. On-line randomized controlled trial of an internet based psychologically enhanced intervention for people with hazardous alcohol consumption. PLoS One. 2011;6(3):e14740. [pmid: 21408060].
25 Walters ST, Vader AM, Harris TR, Field CA, Jouriles EN. Dismantling motivational interviewing and feedback for college drinkers: a randomized clinical trial. J Consult Clin Psychol. 2009;77(1):64-73. [pmid: 19170454].