# SEARCH STRATEGIES

## SEARCH STRATEGIES BY DATABASE

### Database: PubMed

Search date: 8/18/14

Set # | | Results
1 | “Behavior Therapy”[Mesh:NoExp] OR ((behavior[tiab] OR behaviour[tiab]) AND (therapy [tiab] OR therapies[tiab])) OR “Cognitive Therapy”[Mesh] OR ((cognitive[tiab] OR cognition[tiab]) AND (therapy[tiab] OR therapies[tiab])) OR “Psychotherapy, Brief”[Mesh] OR ((brief[tiab] OR short-term[tiab]) AND (psychotherapy[tiab] OR psychotherapies[tiab])) OR “brief counseling”[tiab] OR intervention[tiab] OR interventions[tiab] OR “Health Education”[Mesh] | 668012
2 | “Alcoholism”[Mesh] OR “Alcohol Drinking”[Mesh] OR ((heavy[tiab] OR hazardous[tiab] OR harmful[tiab] OR excessive[tiab] OR problem[tiab] OR binge[tiab] OR controlled[tiab] OR risky[tiab] OR “at risk”[tiab] OR “at-risk”[tiab] OR use[tiab]) AND drink*[tiab] AND (Alcohol[tiab] OR “Alcoholic Beverages”[Mesh])) | 107410
3 | “Therapy, Computer-Assisted”[Mesh] OR “Internet”[Mesh] OR “Cellular Phone”[Mesh] OR “Computers”[Mesh] OR “Computer-assisted”[tiab] OR computerized[tiab] OR “low intensity”[tiab] OR internet[tiab] OR web[tiab] OR “social media”[tiab] OR online[tiab] OR computer[tiab] OR computers[tiab] OR electronic[tiab] OR mobile[tiab] OR smartphone[tiab] OR smartphones[tiab] OR tablet[tiab] OR tablets[tiab] OR self-paced[tiab] OR “health buddy”[tiab] OR e-health[tiab] OR ehealth[tiab] OR m-health [tiab] OR mhealth[tiab] | 584939
4 | #1 AND #2 AND #3 | 746
5 | ((randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR drug therapy[sh] OR randomly[tiab] OR trial[tiab] OR groups[tiab]) NOT (animals[mh] NOT humans[mh]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp])) | 2446984
6 | #4 AND #5; limit to English, 2000 - present | 364

### Database: Embase

Search date: 8/18/2014

Set # | | Results
1 | ‘cognitive therapy’/exp OR ‘behavior therapy’/exp OR ‘behavior modification’/exp OR ‘health education’/exp OR ((‘psychotherapy’/exp OR psychotherapy:ab,ti OR psychotherapies:ab,ti) AND (brief:ab,ti OR ‘short term’:ab,ti)) OR ((behavior:ab,ti OR behaviour:ab,ti) AND (therapy:ab,ti OR therapies:ab,ti)) OR ((cognitive:ab,ti OR cognition:ab,ti) AND (therapy:ab,ti OR therapies:ab,ti)) OR ‘brief counseling’:ab,ti OR intervention:ab,ti OR interventions:ab,ti | 932809
2 | ‘alcoholism’/exp OR ‘drinking behavior’/exp OR ((heavy:ab,ti OR hazardous:ab,ti OR harmful:ab,ti OR excessive:ab,ti OR problem:ab,ti OR binge:ab,ti OR controlled:ab,ti OR risky:ab,ti OR “at risk”:ab,ti OR “at-risk”:ab,ti OR use:ab,ti) AND drink*:ab,ti AND (Alcohol:ab,ti OR ‘alcoholic beverage’/exp)) | 147931
3 | ‘computer assisted therapy’/exp OR ‘mobile phone’/exp OR ‘Internet’/exp OR ‘computer’/exp OR ‘Computer assisted’:ab,ti OR computerized:ab,ti OR ‘low intensity’:ab,ti OR internet:ab,ti OR web:ab,ti OR “social media”:ab,ti OR online:ab,ti OR computer:ab,ti OR computers:ab,ti OR electronic:ab,ti OR mobile:ab,ti OR smartphone:ab,ti OR smartphones:ab,ti OR tablet:ab,ti OR tablets:ab,ti OR self-paced:ab,ti OR ‘health buddy’:ab,ti OR e-health:ab,ti OR ehealth:ab,ti OR m-health:ab,ti OR mhealth:ab,ti | 1496238
4 | #1 AND #2 AND #3 | 1352
5 | (‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random*:ab,ti OR factorial*:ab,ti OR crossover*:ab,ti OR (cross NEAR/1 over*):ab,ti OR placebo*:ab,ti OR (doubl* NEAR/1 blind*):ab,ti OR (singl* NEAR/1 blind*):ab,ti OR assign*:ab,ti OR allocat*:ab,ti OR volunteer*:ab,ti) NOT (‘case report’/exp OR ‘case study’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp) | 1334623
6 | #4 AND #5 | 435
7 | #6 AND [embase]/lim NOT [medline]/lim | 153
8 | #7, 2000 – present, English | 165

### Database: PsycINFO

Search date: 8/18/2014

Set # | | Results
1 | ((DE “Behavior Therapy”) OR (DE “Cognitive Behavior Therapy”)) OR (DE “Cognitive Therapy”) OR (DE “Brief Psychotherapy”) OR (DE “Health Education”) OR TI ( ((behavior OR behaviour) AND (therapy OR therapies[tiab)) OR ((cognitive OR cognition) AND (therapy OR therapies)) OR ((brief OR short-term) AND (psychotherapy OR psychotherapies)) OR “brief counseling” OR intervention OR interventions ) OR AB ( ((behavior OR behaviour) AND (therapy OR therapies[tiab)) OR ((cognitive OR cognition) AND (therapy OR therapies)) OR ((brief OR short-term) AND (psychotherapy OR psychotherapies)) OR “brief counseling” OR intervention OR interventions ) | 276210
2 | (DE “Alcoholism”) OR (DE “Alcohol Drinking Patterns” OR DE “Alcohol Abuse” OR DE “Alcohol Intoxication” OR DE “Social Drinking”) OR ((TI ( heavy OR hazardous OR harmful OR excessive OR problem OR binge OR controlled OR risky OR “at risk” OR “at-risk” OR use ) OR AB ( heavy OR hazardous OR harmful OR excessive OR problem OR binge OR controlled OR risky OR “at risk” OR “at-risk” OR use )) AND (TI (drink*) OR AB (drink*) ) AND (TI Alcohol OR AB Alcohol OR (DE “Alcoholic Beverages”) )) | 53853
3 | (((DE “Computer Assisted Therapy”) OR (DE “Internet”)) OR (DE “Cellular Phones”)) OR (DE “Computers” OR DE “Analog Computers” OR DE “Computer Games” OR DE “Digital Computers” OR DE “Microcomputers”) OR TI ( “Computer-assisted” OR computerized OR “low intensity” OR internet OR web OR “social media” OR online OR computer OR computers OR electronic OR mobile OR smartphone OR smartphones OR tablet OR tablets OR self-paced OR “health buddy” OR e-health OR ehealth OR m-health OR mhealth ) OR AB ( “Computer-assisted” OR computerized OR “low intensity” OR internet OR web OR “social media” OR online OR computer OR computers OR electronic OR mobile OR smartphone OR smartphones OR tablet OR tablets OR self-paced OR “health buddy” OR e-health OR ehealth OR m-health OR mhealth ) | 140406
4 | S1 AND S2 AND S3 | 561
5 | #4 AND #5; Limiters - Publication Year: 2000-; English; Methodology: TREATMENT OUTCOME/CLINICAL TRIAL | 58

### Database: The Cochrane Library

Search date: 8/18/2014

Set # | | Results
1 | MeSH descriptor: [Behavior Therapy] explode all trees OR MeSH descriptor: [Cognitive Therapy] explode all trees OR MeSH descriptor: [Psychotherapy, Brief] explode all trees OR MeSH descriptor: [Health Education] explode all trees OR ((behavior:ab,ti OR behaviour:ab,ti) AND (therapy :ab,ti OR therapies:ab,ti)) OR ((cognitive:ab,ti OR cognition:ab,ti) AND (therapy:ab,ti OR therapies:ab,ti)) OR ((brief:ab,ti OR short-term:ab,ti) AND (psychotherapy:ab,ti OR psychotherapies:ab,ti)) OR “brief counseling”:ab,ti OR intervention:ab,ti OR interventions:ab,ti | 83540
2 | MeSH descriptor: [Alcoholism] explode all trees OR MeSH descriptor: [Alcohol Drinking] explode all trees OR ((heavy:ab,ti OR hazardous:ab,ti OR harmful:ab,ti OR excessive:ab,ti OR problem:ab,ti OR binge:ab,ti OR controlled:ab,ti OR risky:ab,ti OR “at risk”:ab,ti OR “at-risk”:ab,ti OR use:ab,ti) AND drink*:ab,ti AND (Alcohol:ab,ti OR MeSH descriptor: [Alcoholic Beverages] explode all trees | 4523
3 | MeSH descriptor: [Therapy, Computer-Assisted] explode all trees OR MeSH descriptor: [Internet] explode all trees OR MeSH descriptor: [Cellular Phone] explode all trees OR MeSH descriptor: [Computers] explode all trees OR “Computer-assisted”:ab,ti OR computerized:ab,ti OR “low intensity”:ab,ti OR internet:ab,ti OR web:ab,ti OR “social media”:ab,ti OR online:ab,ti OR computer:ab,ti OR computers:ab,ti OR electronic:ab,ti OR mobile:ab,ti OR smartphone:ab,ti OR smartphones:ab,ti OR tablet:ab,ti OR tablets:ab,ti OR self-paced:ab,ti OR “health buddy”:ab,ti OR e-health:ab,ti OR ehealth:ab,ti OR m-health :ab,ti OR mhealth:ab,ti | 31584
4 | #1 AND #2 AND #3 (not limited by date) | 197