# RESULTS

The electronic literature search identified 1,223 citations. Of these, 183 citations were classified as unique systematic review citations meeting the inclusion criteria.24-205 The number of systematic review publications by year is shown in Figure 1 below.

Figure 1 Systematic reviews on acupuncture published January 2005 to March 2013

The number of published reviews is increasing, between 9 and 35 reviews were published each year with a peak at 2012. The 2013 column only shows systematic reviews published between January and March 2013.

For the evidence map, the results of the existing systematic reviews are presented in the priority areas: Pain, Wellness, and Mental Health. The distribution of topics is shown in Figure 2 below.

Figure 2 Research volume by priority topic areas

Of the identified priority areas, the most systematic reviews were published relevant to the indication Pain (N=65). In total, 44 reviews were classified as relevant to Wellness. For the indication Mental Health, the fewest systematic reviews were identified (N=20). A large number of systematic review did not appear to be relevant to any of the priority areas (Other Indication N=48). Six systematic reviews focused on Adverse Events, not the clinical effectiveness of acupuncture.

The specific clinical topics targeted in the existing systematic reviews included pain, headache, migraine, fibromyalgia, myofascial trigger point pain, burning mouth syndrome, ankle sprain, neck disorder, dysmenorrhea, trigeminal neuralgia, analgesia during surgery, anxiety, schizophrenia, depression, posttraumatic stress disorder, dementia, Alzheimer's Disease, chronic fatigue syndrome, addiction in general, cocaine addiction, alcohol addiction, opiate addiction, smoking, opioid withdrawal symptoms, quality of life, exercise performance, hiccups, hot flushes, cancer, menopause-related effects, insomnia, cancer-related fatigue, nausea, cancer treatment-related adverse events, uremic pruritus, vasomotor menopausal symptoms, dry eye, dry mouth, premenstrual syndrome, erectile dysfunction, obesity, irritable bowel syndrome, constipation, Ménière's disease, allergic rhinitis, tinnitus, restless legs, temporomandibular disorders, stroke, Bell's palsy, fertility treatment, arthritis, Parkinson, uterine fibroids, pressure ulcer, traumatic brain injury, spinal cord injury, fetal breech presentation, labor induction, aphasia, blood pressure, glaucoma, epilepsy, respiratory disease, asthma, facial spasm, cervical spondylotic radiculopathy, polycystic ovarian syndrome, and angina pectoris symptoms.