# REFERENCES

1 Derry CJ, Derry S, McQuay HJ, Moore RA. Systematic review of systematic reviews of acupuncture published 1996-2005. Clin Med. Jul-Aug. 2006;6(4):381-386.
2 Ernst E. Systematic review of systematic reviews of acupuncture. Clin Med. Sep-Oct. 2006;6(5):508-509.
3 World Health Organization. Acupuncture: Review and Analysis of Reports on Controlled Clinical Trials. Geneva. World Health Organization. 2003.
4 Ernst E, Lee MS, Choi TY. Acupuncture: does it alleviate pain and are there serious risks? A review of reviews. Pain. Apr. 2011;152(4):755-764. [pmid: 21440191].
5 Ernst E. Acupuncture: what does the most reliable evidence tell us?. J Pain Symptom Manage. Apr. 2009;37(4):709-714. [pmid: 18789644].
6 Ernst E, Pittler MH, Wider B, Boddy K. Acupuncture: its evidence-base is changing. Am J Chin Med. 2007;35(1):21-25. [pmid: 17265547].
7 Lee C, Crawford C, Wallerstedt D, et al. The effectiveness of acupuncture research across components of the trauma spectrum response (tsr): a systematic review of reviews. Syst Rev. 2012;1:46. [pmid: 23067573].
8 Lewith G, Berman B, Cummings M, Filshie J, Fisher P, White A. Systematic review of systematic reviews of acupuncture published 1996-2005. Clin Med. Nov-Dec. 2006;6(6):623-625. author reply 625-626.
9 Ernst E, Lee MS, Choi TY. Acupuncture in obstetrics and gynecology: an overview of systematic reviews. Am J Chin Med. 2011;39(3):423-431. [pmid: 21598411].
10 Ernst E, Lee MS, Choi TY. Acupuncture for insomnia? An overview of systematic reviews. Eur J Gen Pract. Jun. 2011;17(2):116-123. [pmid: 21463162].
11 Kang HS, Jeong D, Kim DI, Lee MS. The use of acupuncture for managing gynaecologic conditions: An overview of systematic reviews. Maturitas. Apr. 2011;68(4):346-354. [pmid: 21376483].
12 Lee MS, Ernst E. Acupuncture for pain: an overview of Cochrane reviews. Chin J Integr Med. Mar. 2011;17(3):187-189. [pmid: 21359919].
13 Ernst E, Lee MS, Choi TY. Acupuncture for depression?: A systematic review of systematic reviews. Eval Health Prof. Dec. 2011;34(4):403-412. [pmid: 21138913].
14 Ernst E, Lee MS. Acupuncture for rheumatic conditions: an overview of systematic reviews. Rheumatology (Oxford). Oct. 2010;49(10):1957-1961. [pmid: 20591833].
15 Smith CA, Carmady B. Acupuncture to treat common reproductive health complaints: An overview of the evidence. Auton Neurosci. Oct. 28. 2010;157(1-2):52-56. [pmid: 20483671].
16 Sherman KJ, Coeytaux RR. Acupuncture for Improving Chronic Back Pain, Osteoarthritis and Headache. J Clin Outcomes Manag. May. 1. 2009;16(5):224-230. [pmid: 20445762].
17 Hopton A, MacPherson H. Acupuncture for chronic pain: is acupuncture more than an effective placebo? A systematic review of pooled data from meta-analyses. Pain Pract. Mar-Apr. 2010;10(2):94-102. [pmid: 20070551].
18 Smith CA, Cochrane S. Does acupuncture have a place as an adjunct treatment during pregnancy? A review of randomized controlled trials and systematic reviews. Birth. Sep. 2009;36(3):246-253. [pmid: 19747272].
19 Ezzo J, Streitberger K, Schneider A. Cochrane systematic reviews examine P6 acupuncture-point stimulation for nausea and vomiting. J Altern Complement Med. Jun. 2006;12(5):489-495. [pmid: 16813514].
20 Zhao XF, Du Y, Liu PG, Wang S. Acupuncture for stroke: evidence of effectiveness, safety, and cost from systematic reviews. Top Stroke Rehabil. May-Jun. 2012;19(3):226-233. [pmid: 22668677].
21 Adams E. Brief Overview: A Summary of the Evidence for Use of Acupuncture From Systematic Reviews and Meta-Analyses. Boston. Veterans Health Administration. 2007.
22 Ma B, Qi GQ, Lin XT, Wang T, Chen ZM, Yang KH. Epidemiology, quality, and reporting characteristics of systematic reviews of acupuncture interventions published in Chinese journals. J Altern Complement Med. Sep. 2012;18(9):813-817. [pmid: 22924413].
23 Vickers A, Goyal N, Harland R, Rees R. Do certain countries produce only positive results? A systematic review of controlled trials. Control Clin Trials. Apr. 1998;19(2):159-166. [pmid: 9551280].
24 Cao H, Pan X, Li H, Liu J. Acupuncture for treatment of insomnia: a systematic review of randomized controlled trials. J Altern Complement Med. Nov. 2009;15(11):1171-1186. [pmid: 19922248].
25 Chen HY, Shi Y, Ng CS, Chan SM, Yung KK, Zhang QL. Auricular acupuncture treatment for insomnia: a systematic review. J Altern Complement Med. Jul-Aug. 2007;13(6):669-676. [pmid: 17718650].
26 Huang W, Kutner N, Bliwise DL. A systematic review of the effects of acupuncture in treating insomnia. Sleep Med Rev. Feb. 2009;13(1):73-104. [pmid: 19097814].
27 Lee MS, Shin BC, Suen LK, Park TY, Ernst E. Auricular acupuncture for insomnia: a systematic review. Int J Clin Pract. Nov. 2008;62(11):1744-1752. [pmid: 18754807].
28 Wong V, Cheuk DK, Lee S, Chu V. Acupuncture for acute management and rehabilitation of traumatic brain injury. Cochrane Database Syst Rev. 2013;3:CD007700. [pmid: 23543554].
29 Chen MN, Chien LW, Liu CF. Acupuncture or Acupressure at the Sanyinjiao (SP6) Acupoint for the Treatment of Primary Dysmenorrhea: A Meta-Analysis. Evid Based Complement Alternat Med. 2013;2013:493038. [pmid: 23533489].
30 Park J, Hahn S, Park JY, Park HJ, Lee H. Acupuncture for ankle sprain: systematic review and meta-analysis. BMC Complement Altern Med. 2013;13:55. [pmid: 23496981].
31 Kim YD, Heo I, Shin BC, Crawford C, Kang HW, Lim JH. Acupuncture for posttraumatic stress disorder: a systematic review of randomized controlled trials and prospective clinical trials. Evid Based Complement Alternat Med. 2013;2013:615857. [pmid: 23476697].
32 Heo I, Shin BC, Kim YD, Hwang EH, Han CW, Heo KH. Acupuncture for spinal cord injury and its complications: a systematic review and meta-analysis of randomized controlled trials. Evid Based Complement Alternat Med. 2013;2013:364216. [pmid: 23476688].
33 Posadzki P, Moon TW, Choi TY, Park TY, Lee MS, Ernst E. Acupuncture for cancer-related fatigue: a systematic review of randomized clinical trials. Support Care Cancer. Feb. 24. 2013.
34 Chen J, Ren Y, Tang Y, Li Z, Liang F. Acupuncture therapy for angina pectoris: a systematic review. J Tradit Chin Med. Dec. 2012;32(4):494-501. [pmid: 23427379].
35 Lee WB, Woo SH, Min BI, Cho SH. Acupuncture for gouty arthritis: a concise report of a systematic and meta-analysis approach. Rheumatology (Oxford). Feb. 18. 2013.
36 Kim KH, Lee BR, Ryu JH, Choi TY, Yang GY. The role of acupuncture in emergency department settings: a systematic review. Complement Ther Med. Feb. 2013;21(1):65-72. [pmid: 23374207].
37 Kong LJ, Fang M, Zhan HS, et al. Tuina-focused integrative chinese medical therapies for inpatients with low back pain: a systematic review and meta-analysis. Evid Based Complement Alternat Med. 2012;2012:578305. [pmid: 23346207].
38 Garcia MK, McQuade J, Haddad R, et al. Systematic review of acupuncture in cancer care: a synthesis of the evidence. J Clin Oncol. Mar. 1. 2013;31(7):952-960. [pmid: 23341529].
39 Xu M, Yan S, Yin X, et al. Acupuncture for chronic low back pain in long-term follow-up: a meta-analysis of 13 randomized controlled trials. Am J Chin Med. 2013;41(1):1-19. [pmid: 23336503].
40 Sun Y, Xue SA, Zuo Z. Acupuncture therapy on apoplectic aphasia rehabilitation. J Tradit Chin Med. Sep. 2012;32(3):314-321. [pmid: 23297549].
41 Wang Y, Shen J, Wang XM, et al. Scalp acupuncture for acute ischemic stroke: a meta-analysis of randomized controlled trials. Evid Based Complement Alternat Med. 2012;2012:480950. [pmid: 23258988].
42 Choi TY, Lee MS, Ernst E. Acupuncture for cancer patients suffering from hiccups: a systematic review and meta-analysis. Complement Ther Med. Dec. 2012;20(6):447-455. [pmid: 23131378].
43 Hutchinson AJ, Ball S, Andrews JC, Jones GG. The effectiveness of acupuncture in treating chronic non-specific low back pain: a systematic review of the literature. J Orthop Surg Res. 2012;7:36. [pmid: 23111099].
44 Clark RJ, Tighe M. The effectiveness of acupuncture for plantar heel pain: a systematic review. Acupunct Med. Dec. 2012;30(4):298-306. [pmid: 23099290].
45 Long YB, Wu XP. A meta-analysis of the efficacy of acupuncture in treating dysphagia in patients with a stroke. Acupunct Med. Dec. 2012;30(4):291-297. [pmid: 23000511].
46 Cheuk DK, Yeung WF, Chung KF, Wong V. Acupuncture for insomnia. Cochrane Database Syst Rev. 2012;9:CD005472. [pmid: 22972087].
47 Vickers AJ, Cronin AM, Maschino AC, et al. Acupuncture for chronic pain: individual patient data meta-analysis. Arch Intern Med. Oct. 22. 2012;172(19):1444-1453. [pmid: 22965186].
48 Lee JA, Park SW, Hwang PW, et al. Acupuncture for shoulder pain after stroke: a systematic review. J Altern Complement Med. Sep. 2012;18(9):818-823. [pmid: 22924414].
49 Zhang F, Kong LL, Zhang YY, Li SC. Evaluation of impact on health-related quality of life and cost effectiveness of traditional chinese medicine: a systematic review of randomized clinical trials. J Altern Complement Med. Dec. 2012;18(12):1108-1120. [pmid: 22924383].
50 Chung YC, Chen HH, Yeh ML. Acupoint stimulation intervention for people with primary dysmenorrhea: Systematic review and meta-analysis of randomized trials. Complement Ther Med. Oct. 2012;20(5):353-363. [pmid: 22863651].
51 Kim JI, Choi JY, Lee DH, Choi TY, Lee MS, Ernst E. Acupuncture for the treatment of tinnitus: a systematic review of randomized clinical trials. BMC Complement Altern Med. 2012;12:97. [pmid: 22805113].
52 Zhuang L, Yang Z, Zeng X, et al. The Preventive and Therapeutic Effect of Acupuncture for Radiation-Induced Xerostomia in Patients With Head and Neck Cancer: A Systematic Review. Integr Cancer Ther. Jul. 16. 2012.
53 Cheng HM, Chung YC, Chen HH, Chang YH, Yeh ML. Systematic review and meta-analysis of the effects of acupoint stimulation on smoking cessation. Am J Chin Med. 2012;40(3):429-442. [pmid: 22745061].
54 Holmer Pettersson P, Wengstrom Y. Acupuncture prior to surgery to minimise postoperative nausea and vomiting: a systematic review. J Clin Nurs. Jul. 2012;21(13-14):1799-1805. [pmid: 22672450].
55 Qu F, Zhou J, Ren RX. Effects of acupuncture on the outcomes of in vitro fertilization: a systematic review and meta-analysis. J Altern Complement Med. May. 2012;18(5):429-439. [pmid: 22540969].
56 Zhang QH, Sun ZR, Yue JH, et al. Traditional Chinese medicine for pressure ulcer: a meta-analysis. Int Wound J. Apr. 2013;10(2):221-231. [pmid: 22512889].
57 Manheimer E, Wieland LS, Cheng K, et al. Acupuncture for irritable bowel syndrome: systematic review and meta-analysis. Am J Gastroenterol. Jun. 2012;107(6):835-847. quiz 848. [pmid: 22488079].
58 Lin JG, Chan YY, Chen YH. Acupuncture for the treatment of opiate addiction. Evid Based Complement Alternat Med. 2012;2012:739045. [pmid: 22474521].
59 Choi TY, Lee MS, Kim TH, Zaslawski C, Ernst E. Acupuncture for the treatment of cancer pain: a systematic review of randomised clinical trials. Support Care Cancer. Jun. 2012;20(6):1147-1158. [pmid: 22447366].
60 Sui Y, Zhao HL, Wong VC, et al. A systematic review on use of Chinese medicine and acupuncture for treatment of obesity. Obes Rev. May. 2012;13(5):409-430. [pmid: 22292480].
61 Zheng CH, Huang GY, Zhang MM, Wang W. Effects of acupuncture on pregnancy rates in women undergoing in vitro fertilization: a systematic review and meta-analysis. Fertil Steril. Mar. 2012;97(3):599-611. [pmid: 22243605].
62 Furlan AD, Yazdi F, Tsertsvadze A, et al. A systematic review and meta-analysis of efficacy, cost-effectiveness, and safety of selected complementary and alternative medicine for neck and low-back pain. Evid Based Complement Alternat Med. 2012;2012:953139. [pmid: 22203884].
63 Standaert CJ, Friedly J, Erwin MW, et al. Comparative effectiveness of exercise, acupuncture, and spinal manipulation for low back pain. Spine (Phila Pa 1976). Oct. 1. 2011;36(21 Suppl):S120-130. [pmid: 21952184].
64 Kim JI, Lee MS, Choi TY, Lee H, Kwon HJ. Acupuncture for Bell's palsy: a systematic review and meta-analysis. Chin J Integr Med. Jan. 2012;18(1):48-55. [pmid: 21994030].
65 Zhu X, Hamilton KD, McNicol ED. Acupuncture for pain in endometriosis. Cochrane Database Syst Rev. 2011;(9):CD007864. [pmid: 21901713].
66 Kim KH, Lee MS, Choi SM. Acupuncture for treating uremic pruritus in patients with end-stage renal disease: a systematic review. J Pain Symptom Manage. Jul. 2010;40(1):117-125. [pmid: 21796811].
67 Smith CA, Collins CT, Crowther CA, Levett KM. Acupuncture or acupressure for pain management in labour. Cochrane Database Syst Rev. 2011;(7):CD009232. [pmid: 21735441].
68 Kim SY, Park HJ, Lee H. Acupuncture for premenstrual syndrome: a systematic review and meta-analysis of randomised controlled trials. BJOG. Jul. 2011;118(8):899-915. [pmid: 21609380].
69 Zhao L, Guo Y, Wang W, Yan LJ. Systematic review on randomized controlled clinical trials of acupuncture therapy for neurovascular headache. Chin J Integr Med. Aug. 2011;17(8):580-586. [pmid: 21526365].
70 Zheng GQ, Zhao ZM, Wang Y, et al. Meta-analysis of scalp acupuncture for acute hypertensive intracerebral hemorrhage. J Altern Complement Med. Apr. 2011;17(4):293-299. [pmid: 21438797].
71 Posadzki P, Zhang J, Lee MS, Ernst E. Acupuncture for chronic nonbacterial prostatitis/chronic pelvic pain syndrome: a systematic review. J Androl. Jan-Feb. 2012;33(1):15-21. [pmid: 21436307].
72 Smith CA, Zhu X, He L, Song J. Acupuncture for primary dysmenorrhoea. Cochrane Database Syst Rev. 2011;(1):CD007854. [pmid: 21249697].
73 Paley CA, Johnson MI, Tashani OA, Bagnall AM. Acupuncture for cancer pain in adults. Cochrane Database Syst Rev. 2011;(1):CD007753. [pmid: 21249694].
74 White AR, Rampes H, Liu JP, Stead LF, Campbell J. Acupuncture and related interventions for smoking cessation. Cochrane Database Syst Rev. 2011;(1):CD000009. [pmid: 21249644].
75 Sim H, Shin BC, Lee MS, Jung A, Lee H, Ernst E. Acupuncture for carpal tunnel syndrome: a systematic review of randomized controlled trials. J Pain. Mar. 2011;12(3):307-314. [pmid: 21093382].
76 O'Sullivan EM, Higginson IJ. Clinical effectiveness and safety of acupuncture in the treatment of irradiation-induced xerostomia in patients with head and neck cancer: a systematic review. Acupunct Med. Dec. 2010;28(4):191-199. [pmid: 21062848].
77 Lu SC, Zheng Z, Xue CC. Does acupuncture improve quality of life for patients with pain associated with the spine? A systematic review. Evid Based Complement Alternat Med. 2011;2011:301767. [pmid: 20976075].
78 Asher GN, Jonas DE, Coeytaux RR, et al. Auriculotherapy for pain management: a systematic review and meta-analysis of randomized controlled trials. J Altern Complement Med. Oct. 2010;16(10):1097-1108. [pmid: 20954963].
79 Shen FY, Lee MS, Jung SK. Effectiveness of pharmacopuncture for asthma: a systematic review and meta-analysis. Evid Based Complement Alternat Med. 2011;2011.
80 Kong JC, Lee MS, Shin BC, Song YS, Ernst E. Acupuncture for functional recovery after stroke: a systematic review of sham-controlled randomized clinical trials. CMAJ. Nov. 9. 2010;182(16):1723-1729. [pmid: 20876268].
81 Chen N, Zhou M, He L, Zhou D, Li N. Acupuncture for Bell's palsy. Cochrane Database Syst Rev. 2010;(8):CD002914. [pmid: 20687071].
82 Kim MK, Choi TY, Lee MS, Lee H, Han CH. Contralateral acupuncture versus ipsilateral acupuncture in the rehabilitation of post-stroke hemiplegic patients: a systematic review. BMC Complement Altern Med. 2010;10:41. [pmid: 20673364].
83 La Touche R, Goddard G, De-la-Hoz JL, et al. Acupuncture in the treatment of pain in temporomandibular disorders: a systematic review and meta-analysis of randomized controlled trials. Clin J Pain. Jul-Aug. 2010;26(6):541-550. [pmid: 20551730].
84 Trigkilidas D. Acupuncture therapy for chronic lower back pain: a systematic review. Ann R Coll Surg Engl. Oct. 2010;92(7):595-598. [pmid: 20529520].
85 Cho SH, Lee H, Ernst E. Acupuncture for pain relief in labour: a systematic review and meta-analysis. BJOG. Jul. 2010;117(8):907-920. [pmid: 20438555].
86 Cho SH, Kim J. Efficacy of acupuncture in management of premenstrual syndrome: a systematic review. Complement Ther Med. Apr. 2010;18(2):104-111. [pmid: 20430293].
87 Li MK, Lee TF, Suen KP. A review on the complementary effects of auriculotherapy in managing constipation. J Altern Complement Med. Apr. 2010;16(4):435-447. [pmid: 20423213].
88 Cao H, Liu J, Lewith GT. Traditional Chinese Medicine for treatment of fibromyalgia: a systematic review of randomized controlled trials. J Altern Complement Med. Apr. 2010;16(4):397-409. [pmid: 20423209].
89 Cho SH, Whang WW. Acupuncture for temporomandibular disorders: a systematic review. J Orofac Pain. Spring. 2010;24(2):152-162. [pmid: 20401353].
90 Lee MS, Shin BC, Choi TY, Ernst E. Acupuncture for treating dry eye: a systematic review. Acta Ophthalmol. Mar. 2011;89(2):101-106. [pmid: 20337604].
91 Lim CE, Wong WS. Current evidence of acupuncture on polycystic ovarian syndrome. Gynecol Endocrinol. Jun. 2010;26(6):473-478. [pmid: 20230329].
92 Cho SH, Hwang EW. Acupuncture for primary dysmenorrhoea: a systematic review. BJOG. Apr. 2010;117(5):509-521. [pmid: 20184568].
93 Wu P, Mills E, Moher D, Seely D. Acupuncture in poststroke rehabilitation: a systematic review and meta-analysis of randomized trials. Stroke. Apr. 2010;41(4):e171-179. [pmid: 20167912].
94 Langhorst J, Klose P, Musial F, Irnich D, Hauser W. Efficacy of acupuncture in fibromyalgia syndrome--a systematic review with a meta-analysis of controlled clinical trials. Rheumatology (Oxford). Apr. 2010;49(4):778-788. [pmid: 20100789].
95 Zhang Y, Peng W, Clarke J, Liu Z. Acupuncture for uterine fibroids. Cochrane Database Syst Rev. 2010;(1):CD007221. [pmid: 20091625].
96 Smith CA, Hay PP, Macpherson H. Acupuncture for depression. Cochrane Database Syst Rev. 2010;(1):CD004046. [pmid: 20091556].
97 Manheimer E, Cheng K, Linde K, et al. Acupuncture for peripheral joint osteoarthritis. Cochrane Database Syst Rev. 2010;(1):CD001977. [pmid: 20091527].
98 Cheong Y, Nardo LG, Rutherford T, Ledger W. Acupuncture and herbal medicine in in vitro fertilisation: a review of the evidence for clinical practice. Hum Fertil (Camb). Mar. 2010;13(1):3-12. [pmid: 20053149].
99 Lin LW, Fu YT, Dunning T, et al. Efficacy of traditional Chinese medicine for the management of constipation: a systematic review. J Altern Complement Med. Dec. 2009;15(12):1335-1346. [pmid: 19958146].
100 Lim CE, Wilkinson JM, Wong WS, Cheng NC. Effect of acupuncture on induction of labor. J Altern Complement Med. Nov. 2009;15(11):1209-1214. [pmid: 19922252].
101 Lee MS, Shin BC, Ronan P, Ernst E. Acupuncture for schizophrenia: a systematic review and meta-analysis. Int J Clin Pract. Nov. 2009;63(11):1622-1633. [pmid: 19832819].
102 Chao LF, Zhang AL, Liu HE, Cheng MH, Lam HB, Lo SK. The efficacy of acupoint stimulation for the management of therapy-related adverse events in patients with breast cancer: a systematic review. Breast Cancer Res Treat. Nov. 2009;118(2):255-267. [pmid: 19760035].
103 Zhang ZJ, Chen HY, Yip KC, Ng R, Wong VT. The effectiveness and safety of acupuncture therapy in depressive disorders: systematic review and meta-analysis. J Affect Disord. Jul. 2010;124(1-2):9-21. [pmid: 19632725].
104 Martin-Sanchez E, Torralba E, Diaz-Dominguez E, Barriga A, Martin JL. Efficacy of acupuncture for the treatment of fibromyalgia: systematic review and meta-analysis of randomized trials. Open Rheumatol J. 2009;3:25-29. [pmid: 19590596].
105 Junhua Z, Menniti-Ippolito F, Xiumei G, et al. Complex traditional Chinese medicine for poststroke motor dysfunction: a systematic review. Stroke. Aug. 2009;40(8):2797-2804. [pmid: 19556527].
106 Long AF, Xing M, Morgan K, Brettle A. Exploring the Evidence Base for Acupuncture in the Treatment of Meniere's Syndrome-A Systematic Review. Evid Based Complement Alternat Med. 2011;2011:429102. [pmid: 19505974].
107 Lee MS, Shin BC, Ernst E. Acupuncture for Alzheimer's disease: a systematic review. Int J Clin Pract. Jun. 2009;63(6):874-879. [pmid: 19490197].
108 Lee MS, Pittler MH, Shin BC, Kim JI, Ernst E. Acupuncture for allergic rhinitis: a systematic review. Ann Allergy Asthma Immunol. Apr. 2009;102(4):269-279. quiz 279-281, 307. [pmid: 19441597].
109 Cho SH, Whang WW. Acupuncture for vasomotor menopausal symptoms: a systematic review. Menopause. Sep-Oct. 2009;16(5):1065-1073. [pmid: 19424092].
110 Cho SH, Whang WW. Acupuncture for alcohol dependence: a systematic review. Alcohol Clin Exp Res. Aug. 2009;33(8):1305-1313. [pmid: 19413653].
111 Lee A, Fan LT. Stimulation of the wrist acupuncture point P6 for preventing postoperative nausea and vomiting. Cochrane Database Syst Rev. 2009;(2):CD003281. [pmid: 19370583].
112 Yeung WF, Chung KF, Leung YK, Zhang SP, Law AC. Traditional needle acupuncture treatment for insomnia: a systematic review of randomized controlled trials. Sleep Med. Aug. 2009;10(7):694-704. [pmid: 19303356].
113 El-Toukhy T, Khalaf Y. The impact of acupuncture on assisted reproductive technology outcome. Curr Opin Obstet Gynecol. Jun. 2009;21(3):240-246. [pmid: 19276803].
114 Moffet HH. Sham acupuncture may be as efficacious as true acupuncture: a systematic review of clinical trials. J Altern Complement Med. Mar. 2009;15(3):213-216. [pmid: 19250001].
115 Li X, Hu J, Wang X, Zhang H, Liu J. Moxibustion and other acupuncture point stimulation methods to treat breech presentation: a systematic review of clinical trials. Chin Med. 2009;4:4. [pmid: 19245719].
116 Lee MS, Shin BC, Ernst E. Acupuncture for treating erectile dysfunction: a systematic review. BJU Int. Aug. 2009;104(3):366-370. [pmid: 19239450].
117 Lee MS, Kim KH, Shin BC, Choi SM, Ernst E. Acupuncture for treating hot flushes in men with prostate cancer: a systematic review. Support Care Cancer. Jul. 2009;17(7):763-770. [pmid: 19224253].
118 Fu LM, Li JT, Wu WS. Randomized controlled trials of acupuncture for neck pain: systematic review and meta-analysis. J Altern Complement Med. Feb. 2009;15(2):133-145. [pmid: 19216662].
119 Madsen MV, Gotzsche PC, Hrobjartsson A. Acupuncture treatment for pain: systematic review of randomised clinical trials with acupuncture, placebo acupuncture, and no acupuncture groups. BMJ. 2009;338:a3115. [pmid: 19174438].
120 Linde K, Allais G, Brinkhaus B, Manheimer E, Vickers A, White AR. Acupuncture for tension-type headache. Cochrane Database Syst Rev. 2009;(1):CD007587. [pmid: 19160338].
121 Linde K, Allais G, Brinkhaus B, Manheimer E, Vickers A, White AR. Acupuncture for migraine prophylaxis. Cochrane Database Syst Rev. 2009;(1):CD001218. [pmid: 19160193].
122 Cho SH, Lee JS, Thabane L, Lee J. Acupuncture for obesity: a systematic review and meta-analysis. Int J Obes (Lond). Feb. 2009;33(2):183-196. [pmid: 19139756].
123 Usichenko TI, Lehmann C, Ernst E. Auricular acupuncture for postoperative pain control: a systematic review of randomised clinical trials. Anaesthesia. Dec. 2008;63(12):1343-1348. [pmid: 19032304].
124 Sun Y, Gan TJ. Acupuncture for the management of chronic headache: a systematic review. Anesth Analg. Dec. 2008;107(6):2038-2047. [pmid: 19020156].
125 Lee H, Kim SY, Park J, Kim YJ, Park HJ. Acupuncture for lowering blood pressure: systematic review and meta-analysis. Am J Hypertens. Jan. 2009;22(1):122-128. [pmid: 19008863].
126 Lee MS, Kim KH, Choi SM, Ernst E. Acupuncture for treating hot flashes in breast cancer patients: a systematic review. Breast Cancer Res Treat. Jun. 2009;115(3):497-503. [pmid: 18982444].
127 Yuan J, Purepong N, Kerr DP, Park J, Bradbury I, McDonough S. Effectiveness of acupuncture for low back pain: a systematic review. Spine (Phila Pa 1976). Nov. 1. 2008;33(23):E887-900. [pmid: 18978583].
128 Kong JC, Lee MS, Shin BC. Randomized clinical trials on acupuncture in korean literature: a systematic review. Evid Based Complement Alternat Med. Mar. 2009;6(1):41-48. [pmid: 18955298].
129 Yang H, Liu CZ, Chen X, et al. Systematic review of clinical trials of acupuncture-related therapies for primary dysmenorrhea. Acta Obstet Gynecol Scand. 2008;87(11):1114-1122. [pmid: 18951224].
130 Cui Y, Wang Y, Liu Z. Acupuncture for restless legs syndrome. Cochrane Database Syst Rev. 2008;(4):CD006457. [pmid: 18843716].
131 Cheuk DK, Wong V. Acupuncture for epilepsy. Cochrane Database Syst Rev. 2008;(4):CD005062. [pmid: 18843676].
132 Wang C, de Pablo P, Chen X, Schmid C, McAlindon T. Acupuncture for pain relief in patients with rheumatoid arthritis: a systematic review. Arthritis Rheum. Sep. 15. 2008;59(9):1249-1256. [pmid: 18759255].
133 Lee MS, Shin BC, Ernst E. Acupuncture for rheumatoid arthritis: a systematic review. Rheumatology (Oxford). Dec. 2008;47(12):1747-1753. [pmid: 18710899].
134 Xie Y, Wang L, He J, Wu T. Acupuncture for dysphagia in acute stroke. Cochrane Database Syst Rev. 2008;(3):CD006076. [pmid: 18646136].
135 Lee MS, Shin BC, Kong JC, Ernst E. Effectiveness of acupuncture for Parkinson's disease: a systematic review. Mov Disord. Aug. 15. 2008;23(11):1505-1515. [pmid: 18618661].
136 Wang H, Qi H, Wang BS, et al. Is acupuncture beneficial in depression: a meta-analysis of 8 randomized controlled trials?. J Affect Disord. Dec. 2008;111(2-3):125-134. [pmid: 18550177].
137 Moffet HH. Traditional acupuncture theories yield null outcomes: a systematic review of clinical trials. J Clin Epidemiol. Aug. 2008;61(8):741-747. [pmid: 18538996].
138 Sun Y, Gan TJ, Dubose JW, Habib AS. Acupuncture and related techniques for postoperative pain: a systematic review of randomized controlled trials. Br J Anaesth. Aug. 2008;101(2):151-160. [pmid: 18522936].
139 van den Berg I, Bosch JL, Jacobs B, Bouman I, Duvekot JJ, Hunink MG. Effectiveness of acupuncture-type interventions versus expectant management to correct breech presentation: a systematic review. Complement Ther Med. Apr. 2008;16(2):92-100. [pmid: 18514911].
140 Davis MA, Kononowech RW, Rolin SA, Spierings EL. Acupuncture for tension-type headache: a meta-analysis of randomized, controlled trials. J Pain. Aug. 2008;9(8):667-677. [pmid: 18499526].
141 Ng EH, So WS, Gao J, Wong YY, Ho PC. The role of acupuncture in the management of subfertility. Fertil Steril. Jul. 2008;90(1):1-13. [pmid: 18440533].
142 Roberts J, Huissoon A, Dretzke J, Wang D, Hyde C. A systematic review of the clinical effectiveness of acupuncture for allergic rhinitis. BMC Complement Altern Med. 2008;8:13. [pmid: 18430229].
143 Ee CC, Manheimer E, Pirotta MV, White AR. Acupuncture for pelvic and back pain in pregnancy: a systematic review. Am J Obstet Gynecol. Mar. 2008;198(3):254-259. [pmid: 18313444].
144 Manheimer E, Zhang G, Udoff L, et al. Effects of acupuncture on rates of pregnancy and live birth among women undergoing in vitro fertilisation: systematic review and meta-analysis. BMJ. Mar. 8. 2008;336(7643):545-549. [pmid: 18258932].
145 Law SK, Li T. Acupuncture for glaucoma. Cochrane Database Syst Rev. 2007;(4):CD006030. [pmid: 17943876].
146 Schneider A, Streitberger K, Joos S. Acupuncture treatment in gastrointestinal diseases: a systematic review. World J Gastroenterol. Jul. 7. 2007;13(25):3417-3424. [pmid: 17659687].
147 Pilkington K, Kirkwood G, Rampes H, Cummings M, Richardson J. Acupuncture for anxiety and anxiety disorders--a systematic literature review. Acupunct Med. Jun. 2007;25(1-2):1-10. [pmid: 17641561].
148 Kalavapalli R, Singareddy R. Role of acupuncture in the treatment of insomnia: a comprehensive review. Complement Ther Clin Pract. Aug. 2007;13(3):184-193. [pmid: 17631261].
149 Anderson BJ, Haimovici F, Ginsburg ES, Schust DJ, Wayne PM. In vitro fertilization and acupuncture: clinical efficacy and mechanistic basis. Altern Ther Health Med. May-Jun. 2007;13(3):38-48. [pmid: 17515023].
150 Peng WN, Zhao H, Liu ZS, Wang S. Acupuncture for vascular dementia. Cochrane Database Syst Rev. 2007;(2):CD004987. [pmid: 17443563].
151 Trinh K, Graham N, Gross A, et al. Acupuncture for neck disorders. Spine (Phila Pa 1976). Jan. 15. 2007;32(2):236-243. [pmid: 17224820].
152 White A, Foster NE, Cummings M, Barlas P. Acupuncture treatment for chronic knee pain: a systematic review. Rheumatology (Oxford). Mar. 2007;46(3):384-390. [pmid: 17215263].
153 Mayhew E, Ernst E. Acupuncture for fibromyalgia--a systematic review of randomized clinical trials. Rheumatology (Oxford). May. 2007;46(5):801-804. [pmid: 17189243].
154 Helmreich RJ, Shiao SY, Dune LS. Meta-analysis of acustimulation effects on nausea and vomiting in pregnant women. Explore (NY). Sep-Oct. 2006;2(5):412-421. [pmid: 16979105].
155 Kwon YD, Pittler MH, Ernst E. Acupuncture for peripheral joint osteoarthritis: a systematic review and meta-analysis. Rheumatology (Oxford). Nov. 2006;45(11):1331-1337. [pmid: 16936326].
156 Leo RJ, Ligot JS Jr. A systematic review of randomized controlled trials of acupuncture in the treatment of depression. J Affect Disord. Jan. 2007;97(1-3):13-22. [pmid: 16899301].
157 Wu HM, Tang JL, Lin XP, et al. Acupuncture for stroke rehabilitation. Cochrane Database Syst Rev. 2006;(3):CD004131. [pmid: 16856031].
158 Shiao SY, Dune LS. Metaanalyses of acustimulations: effects on nausea and vomiting in postoperative adult patients. Explore (NY). May. 2006;2(3):202-215. [pmid: 16781643].
159 Jordan JB. Acupuncture treatment for opiate addiction: a systematic review. J Subst Abuse Treat. Jun. 2006;30(4):309-314. [pmid: 16716845].
160 Passalacqua G, Bousquet PJ, Carlsen KH, et al. ARIA update: I--Systematic review of complementary and alternative medicine for rhinitis and asthma. J Allergy Clin Immunol. May. 2006;117(5):1054-1062. [pmid: 16675332].
161 Ezzo JM, Richardson MA, Vickers A, et al. Acupuncture-point stimulation for chemotherapy-induced nausea or vomiting. Cochrane Database Syst Rev. 2006;(2):CD002285. [pmid: 16625560].
162 Gates S, Smith LA, Foxcroft DR. Auricular acupuncture for cocaine dependence. Cochrane Database Syst Rev. 2006;(1):CD005192. [pmid: 16437523].
163 Kim YH, Schiff E, Waalen J, Hovell M. Efficacy of acupuncture for treating cocaine addiction: a review paper. J Addict Dis. 2005;24(4):115-132. [pmid: 16368661].
164 Rathbone J, Xia J. Acupuncture for schizophrenia. Cochrane Database Syst Rev. 2005;(4):CD005475. [pmid: 16235404].
165 Casimiro L, Barnsley L, Brosseau L, et al. Acupuncture and electroacupuncture for the treatment of rheumatoid arthritis. Cochrane Database Syst Rev. 2005;(4):CD003788. [pmid: 16235342].
166 Mukaino Y, Park J, White A, Ernst E. The effectiveness of acupuncture for depression--a systematic review of randomised controlled trials. Acupunct Med. Jun. 2005;23(2):70-76. [pmid: 16025787].
167 Green S, Buchbinder R, Hetrick S. Acupuncture for shoulder pain. Cochrane Database Syst Rev. 2005;(2):CD005319. [pmid: 15846753].
168 Zhang SH, Liu M, Asplund K, Li L. Acupuncture for acute stroke. Cochrane Database Syst Rev. 2005;(2):CD003317. [pmid: 15846657].
169 Manheimer E, White A, Berman B, Forys K, Ernst E. Meta-analysis: acupuncture for low back pain. Ann Intern Med. Apr. 19. 2005;142(8):651-663. [pmid: 15838072].
170 Furlan AD, van Tulder M, Cherkin D, et al. Acupuncture and dry-needling for low back pain: an updated systematic review within the framework of the cochrane collaboration. Spine (Phila Pa 1976). Apr. 15. 2005;30(8):944-963. [pmid: 15834340].
171 Lee H, Ernst E. Acupuncture analgesia during surgery: a systematic review. Pain. Apr. 2005;114(3):511-517. [pmid: 15777876].
172 Mills EJ, Wu P, Gagnier J, Ebbert JO. Efficacy of acupuncture for cocaine dependence: a systematic review & meta-analysis. Harm Reduct J. Mar. 17. 2005;2(1):4. [pmid: 15771785].
173 Stener-Victorin E. The pain-relieving effect of electro-acupuncture and conventional medical analgesic methods during oocyte retrieval: a systematic review of randomized controlled trials. Hum Reprod. Feb. 2005;20(2):339-349. [pmid: 15539440].
174 Acupuncture and other physical treatments for the relief of chronic pain due to osteoarthritis of the knee: a systematic review and network meta-analysis (Provisional abstract). Database of Abstracts of Reviews of Effects. 2012;(1):206. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12012028486/frame.html.
175 Carpenter JS, Neal JG. Other complementary and alternative medicine modalities: acupuncture, magnets, reflexology, and homeopathy (Provisional abstract). American Journal of Medicine. 2005;(12 Supplement B):109-117. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12006003041/frame.html. Published Wellness-Menopause. [pmid: 16414335].
176 Jedel E, Carlsson J. Acupuncture in the management of tension-type headache (Provisional abstract). Physical Therapy Reviews. 2005;(3):131-139. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12005008653/frame.html.
177 Selfe TK, Taylor AG. Acupuncture and osteoarthritis of the knee: a review of randomized controlled trials (Structured abstract). Family and Community Health. 2008;(3):247-254. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12008104955/frame.html. [pmid: 18552606].
178 Tough EA, White AR. Effectiveness of acupuncture/dry needling for myofascial trigger point pain (Provisional abstract). Physical Therapy Reviews. 2011;(2):147-154. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12011006164/frame.html.
179 Lua PL, Talib NS. The effectiveness of auricular acupuncture for drug addiction: a review of research evidence from clinical trials. ASEAN Journal of Psychiatry. 2012;13(1):55-68.
180 Yan Z, Ding N, Hua H. A systematic review of acupuncture or acupoint injection for management of burning mouth syndrome. Quintessence Int. Sep. 2012;43(8):695-701. [pmid: 23034422].
181 Liu H, Li H, Xu M, Chung KF, Zhang SP. A systematic review on acupuncture for trigeminal neuralgia. Altern Ther Health Med. Nov-Dec. 2010;16(6):30-35. [pmid: 21280460].
182 Lee JH, Choi TY, Lee MS, Lee H, Shin BC. Acupuncture for acute low back pain: a systematic review. Clin J Pain. Feb. 2013;29(2):172-185. [pmid: 23269281].
183 Hao XA, Xue CC, Dong L, Zheng Z. Factors associated with conflicting findings on acupuncture for tension-type headache: qualitative and quantitative analyses. J Altern Complement Med. Apr. 2013;19(4):285-297. [pmid: 23075410].
184 Dos Santos S, Hill N, Morgan A, Smith J, Thai C, Cheifetz O. Acupuncture for treating common side effects associated with breast cancer treatment: a systematic review (Provisional abstract). Medical Acupuncture. 2010;(2):81-97. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12010004956/frame.html.
185 Jedel E. Acupuncture in xerostomia--a systematic review. J Oral Rehabil. Jun. 2005;32(6):392-396. [pmid: 15899016].
186 Lee MS, Shin BC, Ernst E. Acupuncture for treating menopausal hot flushes: a systematic review. Climacteric. Feb. 2009;12(1):16-25. [pmid: 19116803].
187 Urroz P, Colagiuri B, Smith CA, Cheema BS. Effect of acute acupuncture treatment on exercise performance and postexercise recovery: a systematic review. J Altern Complement Med. Jan. 2013;19(1):9-16. [pmid: 22967279].
188 Liu TT, Shi J, Epstein DH, Bao YP, Lu L. A meta-analysis of acupuncture combined with opioid receptor agonists for treatment of opiate-withdrawal symptoms. Cell Mol Neurobiol. Jun. 2009;29(4):449-454. [pmid: 19109766].
189 Wang T, Zhang Q, Xue X, Yeung A. A systematic review of acupuncture and moxibustion treatment for chronic fatigue syndrome in China. Am J Chin Med. 2008;36(1):1-24. [pmid: 18306446].
190 Zhang GC, Fu WB, Xu NG, et al. Meta analysis of the curative effect of acupuncture on post-stroke depression. J Tradit Chin Med. Mar. 2012;32(1):6-11. [pmid: 22594095].
191 Kim LW, Zhu J. Acupuncture for essential hypertension (Provisional abstract). Alternative Therapies in Health and Medicine. 2010;(2):18-29. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12010002948/frame.html. [pmid: 20232615].
192 Touche R, Angulo-Diaz-Parreno S, de-la-Hoz JL, et al. Effectiveness of acupuncture in the treatment of temporomandibular disorders of muscular origin: a systematic review of the last decade (Structured abstract). Journal of Alternative and Complementary Medicine. 2010;(1):107-112. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12010002321/frame.html. [pmid: 20038262].
193 Cao L, Zhang XL, Gao YS, Jiang Y. Needle acupuncture for osteoarthritis of the knee. A systematic review and updated meta-analysis. Saudi Med J. May. 2012;33(5):526-532. [pmid: 22588814].
194 Ernst E, Lee MS. A trial design that generates only ‘'positive” results. J Postgrad Med. Jul-Sep. 2008;54(3):214-216. [pmid: 18626172].
195 Jung A, Shin BC, Lee MS, Sim H, Ernst E. Acupuncture for treating temporomandibular joint disorders: a systematic review and meta-analysis of randomized, sham-controlled trials. J Dent. May. 2011;39(5):341-350. [pmid: 21354460].
196 Lu W, Hu D, Dean-Clower E, et al. Acupuncture for chemotherapy-induced leukopenia: exploratory meta-analysis of randomized controlled trials. J Soc Integr Oncol. Winter. 2007;5(1):1-10. [pmid: 17309808].
197 Suzuki M, Yokoyama Y, Yamazaki H. Research into acupuncture for respiratory disease in Japan: a systematic review. Acupunct Med. Jun. 2009;27(2):54-60. [pmid: 19502460].
198 Wang QP, Bai M, Lei D. Effectiveness of acupuncture in treatment of facial spasm: a meta-analysis. Altern Ther Health Med. May-Jun. 2012;18(3):45-52. [pmid: 22875561].
199 Wong IS, Ng KF, Tsang HW. Acupuncture for dysphagia following stroke: a systematic review. European Journal of Integrative Medicine. 2012;4(2):e141-e150.
200 Xu S, Wang L, Cooper E, et al. Adverse events of acupuncture: a systematic review of case reports. Evid Based Complement Alternat Med. 2013;2013:581203. [pmid: 23573135].
201 Bergqvist D. Vascular injuries caused by acupuncture. A systematic review. Int Angiol. Feb. 2013;32(1):1-8. [pmid: 23435388].
202 He W, Zhao X, Li Y, Xi Q, Guo Y. Adverse events following acupuncture: a systematic review of the Chinese literature for the years 1956-2010. J Altern Complement Med. Oct. 2012;18(10):892-901. [pmid: 22967282].
203 Zhang J, Shang H, Gao X, Ernst E. Acupuncture-related adverse events: a systematic review of the Chinese literature. Bull World Health Organ. Dec. 1. 2010;88(12):915-921C. [pmid: 21124716].
204 Ernst E, Zhang J. Cardiac tamponade caused by acupuncture: a review of the literature. Int J Cardiol. Jun. 16. 2011;149(3):287-289. [pmid: 21093944].
205 Yamashita H, Masuyama S, Otsuki K, Tsukayama H. Safety of acupuncture for osteoarthritis of the knee: a review of randomised controlled trials, focusing on specific reactions to acupuncture (Structured abstract). Acupuncture in Medicine. 2006;(Supplement):S49-s52. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12007001077/frame.html.
206 Suarez-Almazor ME, Looney C, Liu Y, et al. A randomized controlled trial of acupuncture for osteoarthritis of the knee: effects of patient-provider communication. Arthritis Care Res (Hoboken). Sep. 2010;62(9):1229-1236. [pmid: 20506122].
207 Pittler MH, Ernst E. Complementary therapies for reducing body weight: a systematic review. Int J Obes (Lond). Sep. 2005;29(9):1030-1038. [pmid: 15925954].
208 Brinkhaus B, Witt CM, Jena S, Liecker B, Wegscheider K, Willich SN. Acupuncture in patients with allergic rhinitis: a pragmatic randomized trial. Ann Allergy Asthma Immunol. Nov. 2008;101(5):535-543. [pmid: 19055209].
209 Zhang CX, Guto LK, Guo BR. Clinical efficacy of electroacupuncture combined with dalitong granule for gastroesophageal reflux disease and its mechanism. Zhongguo Zhen Jiu. Jun. 2012;32(6):491-498. [pmid: 22741253].
210 Ma TT, Yu SY, Li Y, et al. Randomised clinical trial: an assessment of acupuncture on specific meridian or specific acupoint vs. sham acupuncture for treating functional dyspepsia. Aliment Pharmacol Ther. Mar. 2012;35(5):552-561. [pmid: 22243034].
211 Han J. Observation on effect of acupuncture at Yuji (LU 10) on the pulmonary function of patients with bronchial asthma and immediate efficacy of relieving asthma. Zhongguo Zhen Jiu. Oct. 2012;32(10):891-894. [pmid: 23259263].
212 Bergqvist D. Vascular injuries caused by acupuncture. Eur J Vasc Endovasc Surg. Aug. 2008;36(2):160-163. [pmid: 18538597].
213 Zheng CH, Zhang MM, Huang GY, Wang W. The role of acupuncture in assisted reproductive technology. Evid Based Complement Alternat Med. 2012;2012:543924. [pmid: 22811747].
214 Haake M, Muller HH, Schade-Brittinger C, et al. German Acupuncture Trials (GERAC) for chronic low back pain: randomized, multicenter, blinded, parallel-group trial with 3 groups. Arch Intern Med. Sep. 24. 2007;167(17):1892-1898. [pmid: 17893311].
215 Lund I, Lundeberg T. Are minimal, superficial or sham acupuncture procedures acceptable as inert placebo controls?. Acupunct Med. Mar. 2006;24(1):13-15. [pmid: 16618044].
216 Zhang H, Bian Z, Lin Z. Are acupoints specific for diseases? A systematic review of the randomized controlled trials with sham acupuncture controls. Chin Med. 2010;5:1. [pmid: 20145733].
217 Linde K, Niemann K, Schneider A, Meissner K. How large are the nonspecific effects of acupuncture? A meta-analysis of randomized controlled trials (Provisional abstract). BMC Medicine. 2010;(1):75. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12011001754/frame.html. [pmid: 21092261].
218 Moroz A, Freed B, Tiedemann L, Bang H, Howell M, Park JJ. Blinding measured: a systematic review of randomized controlled trials of acupuncture. Evid Based Complement Alternat Med. 2013;2013:708251. [pmid: 23533515].
219 White A, Foster N, Cummings M, Barlas P. The effectiveness of acupuncture for osteoarthritis of the knee: a systematic review. Acupunct Med. Dec. 2006;24:40-48.
220 Shi GX, Yang XM, Liu CZ, Wang LP. Factors contributing to therapeutic effects evaluated in acupuncture clinical trials. Trials. 2012;13:42. [pmid: 22520963].
221 MacPherson H, Hammerschlag R. Acupuncture and the emerging evidence base: contrived controversy and rational debate. J Acupunct Meridian Stud. Aug. 2012;5(4):141-147. [pmid: 22898062].
222 Liu YQ, Ma LX, Xing JM, et al. Does Traditional Chinese Medicine pattern affect acupoint specific effect? Analysis of data from a multicenter, randomized, controlled trial for primary dysmenorrhea. J Altern Complement Med. Jan. 2012;19(1):43-49. [pmid: 22823583].
223 He L, Zhou MK, Zhou D, Li N, Wu B. Acupuncture for Bell's palsy: a systematic review. Chinese Journal of Evidence-Based Medicine. 2005;5(2):106-109. 129.
224 Yeung WF, Chung KF, Poon MM, et al. Prescription of chinese herbal medicine and selection of acupoints in pattern-based traditional chinese medicine treatment for insomnia: a systematic review. Evidence-Based Complementary and Alternative Medicine. 2012. Article Number 902578.
225 Zheng H, Chen M, Wu X, Li Y, Liang FR. Manage migraine with acupuncture: a review of acupuncture protocols in randomized controlled trials. Am J Chin Med. 2010;38(4):639-650. [pmid: 20626050].
226 Prady SL, Burch J, Crouch S, Macpherson H. Controlling practitioner-patient relationships in acupuncture trials: a systematic review and meta-regression. Acupunct Med. Mar. 15. 2013.
227 Kim SY, Lee H, Chae Y, Park HJ. A systematic review of cost-effectiveness analyses alongside randomised controlled trials of acupuncture. Acupunct Med. Dec. 2012;30(4):273-285. [pmid: 23099289].
228 Li Y, Liu LA, Zhao L, et al. Acupuncture and moxibustion for peripheral facial palsy at different stages: multi-central large-sample randomized controlled trial. Zhongguo Zhen Jiu. Apr. 2011;31(4):289-293. [pmid: 21528591].
229 Berle C, Cobbin D, Smith N, Zaslawski C. An innovative method to accommodate Chinese medicine pattern diagnosis within the framework of evidence-based medical research. Chin J Integr Med. Nov. 2011;17(11):824-833. [pmid: 22057411].
230 MacPherson H, Altman DG, Hammerschlag R, et al. Revised STandards for Reporting Interventions in Clinical Trials of Acupuncture (STRICTA): Extending the CONSORT statement. J Evid Based Med. Aug. 2010;3(3):140-155. [pmid: 21349059].
231 Lee S, Kim JE, Kim JH, Kim TH, Choi SM. Acupuncture and related interventions for treating plantar heel pain in adults. Cochrane Database of Systematic Reviews. 2013;(2). http://onlinelibrary.wiley.com/doi/10.1002/14651858.CD010394/abstract.
232 Uthman Olalekan A, Uthman Rashidah T. Acupuncture for renal colic. Cochrane Database of Systematic Reviews: Reviews. 2012;(1).
233 Lim Chi Eung D, Ng Rachel WC, Chen W, Cheng Nga Chong L, Zaslawski C, Li X. Acupuncture for primary hypercholesterolaemia. Cochrane Database of Systematic Reviews. 2012;(12). http://onlinelibrary.wiley.com/doi/10.1002/14651858.CD010286/abstract.
234 Li Zj, Liang Fr, Chen J, et al. Acupuncture for sudden idiopathic sensorineural hearing loss. Cochrane Database of Systematic Reviews: Reviews. 2012;(1).
235 Lee Shao C, Gyte Gillian ML, Dou L. Acupuncture for turning a breech baby in pregnancy. Cochrane Database of Systematic Reviews: Reviews. 2012;(1).
236 Kim Kun H, Lee Myeong S, Choi TY, Kim TH, Ernst E. Acupuncture for symptomatic gastroparesis. Cochrane Database of Systematic Reviews: Reviews. 2012;(2).
237 Cao H, Wang Y, Zhao H, Liu Jian P, Han M. Acupuncture for chronic constipation. Cochrane Database of Systematic Reviews. 2012;(11). http://onlinelibrary.wiley.com/doi/10.1002/14651858.CD004117.pub3/abstract.
238 Wang Y, Zhishun L, Peng W. Acupuncture for stress urinary incontinence in adults. Cochrane Database of Systematic Reviews: Reviews. 2011;(10).
239 Wang E, Saxena M. Acupuncture for neuropathic pain in adults. Cochrane Database of Systematic Reviews: Reviews. 2011;(2).
240 Liang Cui M, Peng W, Ma Xiao J. Acupuncture for post-stroke upper limb pain. Cochrane Database of Systematic Reviews: Reviews. 2011;(4).
241 Lee Myeong S, Lee DH, Kim JI, Shin BC, Ernst E. Acupuncture for allergic rhinitis. Cochrane Database of Systematic Reviews: Reviews. 2011;(9).
242 Kim TH, Lee Myeong S, Kim Kun H, Kang Jung W, Choi TY, Ernst E. Acupuncture for treating acute ankle sprains in adults. Cochrane Database of Systematic Reviews: Reviews. 2011;(4).
243 Kim TH, Lee Myeong S, Kim Kun H, Kang Jung W, Choi TY, Ernst E. Acupuncture for angina pectoris. Cochrane Database of Systematic Reviews: Reviews. 2011;(3).
244 Kim Kun H, Lee Myeong S, Kim TH, Kang Jung W, Choi TY, Lee Jae D. Acupuncture and related interventions for the symptoms of chronic kidney disease. Cochrane Database of Systematic Reviews: Reviews. 2011;(11).
245 Furlan Andrea D, Yazdi F, Tsertsvadze A, et al. Acupuncture for (sub)acute non-specific low-back pain. Cochrane Database of Systematic Reviews: Reviews. 2011;(8).
246 Yang J, Feng Y, Ying L, et al. Acupuncture for hypertension. Cochrane Database of Systematic Reviews. 2010;(11). http://onlinelibrary.wiley.com/doi/10.1002/14651858.CD008821/abstract.
247 Li J, Lu Y, Shi Yu M, Lenon G, Shi Y. Acupuncture for overweight or obese people. Cochrane Database of Systematic Reviews. 2010;(7). http://onlinelibrary.wiley.com/doi/10.1002/14651858.CD008612/abstract.
248 Lan L, Zeng F, Liu Guang J, Ying L, Wu X, Liu Lan M. Acupuncture for functional dyspepsia. Cochrane Database of Systematic Reviews: Reviews. 2010;(4).
249 Cui Y, Zhishun L, Marchese M, Lee Myeong S, Wang J, Niu J. Acupuncture for multiple sclerosis. Cochrane Database of Systematic Reviews. 2010;(1). http://onlinelibrary.wiley.com/doi/10.1002/14651858.CD008210/abstract.