# OTHER INDICATIONS

Only 2 indications that were not already included in the priority areas Pain, Wellness, or Mental Health were identified that were addressed in 3 or more systematic reviews. The unique topics are presented in the Future Research section.

A large number of individual studies and 9 recent systematic reviews have been published relating to stroke rehabilitation; a 2012 meta-analysis on the efficacy of acupuncture in treating dysphagia in patients with a stroke included 72 RCTs. The review reported that the effectiveness of treatment was higher in the acupuncture group compared to control (OR 5.17, CI: 4.18, 6.38).45 However, the review was primarily based on non-PubMed indexed studies; a 2008 Cochrane review on the same topic included only one RCT and concluded that there is not enough evidence to make any conclusion about the therapeutic effect of acupuncture. A review published in 2012 which aimed to update the Cochrane review included 9 RCTs; it reported that acupuncture combined with conventional rehabilitation has positive effects on dysphagia but given the methodology of the studies more research is needed before recommending acupuncture as a standard treatment to patients.199 A further Cochrane review, last updated in 2009, on stroke rehabilitation concluded there is no clear evidence on the effects of acupuncture on subacute or chronic stroke.157 A third, independent Cochrane review on acupuncture for acute stroke concluded that there is no clear evidence of benefit.168

In addition, one systematic review on apoplectic aphasia rehabilitation was identified that did not provide sufficient data to be combined with the other stroke reviews; the review concluded that controlled clinical studies and a systematic review demonstrate that acupuncture has therapeutic effects on aphasia after stroke.40

A second topic, acupuncture to support fertility treatment, has also received substantial research attention; a systematic review on effects of acupuncture on pregnancy rates in women undergoing in vitro fertilization included 24 RCTs.61 There were conflicting results across the 6 recent systematic reviews on the topic performed by independent researcher groups. While the largest review concluded that acupuncture improves clinical pregnancy rate and live birth rate, a 2010 publication based on a Cochrane review concluded that there is no evidence of benefit in the use of acupuncture during assisted conception.98

In addition, one relevant systematic review was identified that did not report on a passive control group; the review concluded that although acupuncture has gained increasing popularity in the management of subfertility, its effectiveness has remained controversial.141