# ONGOING RESEARCH

This broad overview over the evidence on acupuncture concentrated on the clinical effectiveness of acupuncture. This did not consider systematic reviews on the more refined existing open questions such as the optimal acupuncture pattern and pressure points,224 the comparative effectiveness of existing acupuncture protocols,225 effects of the practitioner,226 cost-effectiveness considerations,227 or the optimal intervention time for acupuncture.228 Furthermore, the use of standardized treatments may not be the optimal treatment for individual patients. Traditional acupuncture involves tailoring treatments to the individual person and innovative methods may be necessary to evaluate acupuncture within the framework of evidence-based medicine.229

Individual future research studies on the clinical effectiveness of acupuncture should comply with the revised STandards for Reporting Interventions in Clinical Trials of Acupuncture (STRICTA).230

We identified Cochrane review protocols for acupuncture published in the last 3 years for treating plantar heel pain,231 renal colic,232 primary hypercholesterolaemia,233 hearing loss,234 breech baby in pregnancy,235 gastroparesis,236 chronic constipation,237 urinary incontinence,238 neuropathic pain,239 post-stroke upper limb pain,240 allergic rhinitis,241 ankle sprains,242 angina pectoris,243 chronic kidney disease,244 back pain,245 hypertension,246 obesity,247 dyspepsia,248 and multiple sclerosis249 indicating ongoing reviews. A search of the international registry of systematic reviews PROSPERO in September 2013 identified 9 ongoing systematic reviews on acupuncture and postoperative gastroparesis syndrome, osteoarthritis, chronic pulmonary obstruction disease, headache, neck pain, phantom limb pain, heel pain, cortisol levels, and pregnancy rates; 2 ongoing reviews of reviews on stroke rehabilitation and surgical conditions; and 2 reviews on semen quality and on diabetic peripheral neuropathy were listed as completed but not published in time for this evidence map [web access 9/23/2013].