# METHODS

This systematic review of systematic reviews provides an overview of the existing literature on acupuncture.

## INCLUSION CRITERIA

To be included in the review of reviews, studies had to meet the following criteria:

- Participants: Reviews and new RCTs including human adult participants undergoing acupuncture for any health-related indication were eligible for inclusion in the evidence map. Reviews and new RCTs in adult participants or not further specified age groups were included; reviews and new RCTs exclusively focusing on animals and exclusively focusing on children were excluded.
- Intervention: Reviews and new RCTs of effects of acupuncture using needles, including traditional Chinese acupuncture and other related acupuncture concepts, with or without electro stimulation, with or without moxibustion, and whole body as well as microsystem acupuncture, were eligible. Reviews or RCTs exclusively targeting acupressure, laser acupuncture, transcutaneous electrical nerve simulation, or dry needling were excluded. Reviews on the effectiveness of acupuncture, alone or in combination with other traditional Chinese medicine approaches, were included. Reviews of clinical indications that included studies of acupuncture among many other interventions, and broad reviews on complementary and alternative medicine approaches without particular focus on acupuncture were not sought. Studies addressing the mechanism of action and correlates of acupuncture (eg, brain activity), or investigating the comparative effectiveness of different acupuncture regimes were excluded.
- Comparator (design): Systematic reviews focusing on acupuncture and summarizing primary research studies were eligible. Reviews either identified as “systematic review” in the title or abstract of the publication or reporting the search sources in the abstract were included. In addition, recent, large (N≥500 participants) RCTs focusing on acupuncture, reporting patient outcomes, and not yet included in existing reviews were included. RCTs had to report on the sample size or be described as a multicenter study in the title or abstract to be considered.
- Outcome: Patient outcomes addressed in reviews or trials were eligible. Reviews and RCTs of provider outcomes, acceptance, prevalence, use, costs, study design features, or intervention features not reporting patient health outcomes in the abstract were excluded.
- Timing: Reviews and new RCTs including any intervention duration and any follow-up point were eligible for inclusion. Reviews had to be published in or after 2005 to be included, regardless of the publication date of the included studies in the review. Of the recent RCTs, only those not yet included in existing systematic reviews were considered.
- Setting: Reviews and recent RCTs in healthcare-related settings were eligible.
- English-language reviews, regardless of the language of the included studies, and recent, large RCTs were eligible for inclusion in the review of reviews.

## SEARCH

For this project, we searched the electronic databases PubMed using the systematic review clinical query; the Database of Abstracts of Reviews of Effects (DARE), a database dedicated to catalogue systematic reviews in healthcare; the Cochrane Library of Systematic Reviews which keeps a record of all ongoing and completed Cochrane reviews; and AMED, the Allied and Complementary Medicine database, in March 2013 to identify English-language systematic reviews published since 2005 focusing on acupuncture. In addition, we identified relevant reviews through the review registry PROSPERO, published reviews of reviews, and topic experts.

Recently published, large acupuncture RCTs indexed in PubMed and not yet included in existing systematic review were identified in topic specific searches using the Randomized Controlled Trial filter in PubMed.

## PROCEDURE

In the first step, we identified systematic reviews meeting the inclusion criteria and removed data duplicates from the database so that the data from each review entered the dataset only once. This entailed identifying and consolidating online-only and final publication of articles, Cochrane reviews published in the Cochrane database and in a journal article, multiple updates of Cochrane reviews, and references to systematic reviews differently indexed in general and specialist systematic review databases. Where originals and updates of systematic reviews by the same author group were available only the most recent version was considered. These systematic reviews were then coded by clinical topic.

Reviews and recent RCTs identified as potentially relevant and all unclear citations were ordered as full text to evaluate the publication against the specified inclusion criteria. The literature flow was documented in an electronic database. Reasons for exclusion of full text publications were recorded. Results of individual reviews and recent RCTs were extracted in an online database for systematic reviews.

## DATA SYNTHESIS

We grouped the identified reviews and trials into the 3 VA priority areas: Pain, Wellness, and Mental Health. In addition, we added categories for Other Indications and for Adverse Events. General acupuncture reviews that could not be categorized as addressing pain, wellness, or mental health were included in the Other Indication domain. Topics of other indications were only eligible for synthesis if at least 3 systematic reviews or recent large RCTs were available for the specific topic.

Topic grouping into the priority domains was guided by a technical expert panel. All reviews focusing on pain regardless of the underlying condition were assigned to the Pain domain. The Wellness domain was used as a broad category covering a wide range of clinical indications and outcomes. This included reviews of indication-unspecific outcomes such as quality of life, reviews of treatments for chronic conditions that reported on symptoms that could be experienced by generally healthy people such as nausea, and reviews of very common conditions such as insomnia. The Mental Health domain covered core mental health conditions and chronic fatigue syndrome due to the use of mental health outcomes in the review. Topics were classified as Other Indication if they did not fit into the VA priority groups. Reviews on adverse events were assigned to the Adverse Event category if they did not report on the therapeutic effectiveness of acupuncture as well. Where possible, reviews were assigned to one topic only based on the primary focus of the review rather than incorporated multiple times into the evidence synthesis.

## BUBBLE PLOTS

The evidence base was distilled into a visual overview of each of the 3 VA priority areas using a bubble plot format. In order to be included in the bubble plots, reviews had to report effect sizes for patient health outcomes for each included study or a pooled result across included studies; present the citations for included studies so that the evidence was identifiable; report on RCT data; and report the effects of passive-controlled studies. We extracted the specific topic (eg, depression treatment), the number of included RCTs, and the size of the treatment effect for the main patient outcomes according to passive-controlled RCT data, from each included systematic review with bubble plot-relevant data. We also extracted additional review characteristics such as whether the review was a Cochrane review or an independent patient data (IPD) review, whether the review showed a positive treatment effect in assessor-blinded RCTs, and whether a majority of studies included in the review not indexed in PubMed.

The bubble plots displays information about the research area in 3 dimensions: the estimated literature size (y-axis), the estimated treatment effect (x-axis), and the confidence in the reported effect (bubble size). Given the format, the large number of existing reviews, and the scope of this project, the bubble plots can only represent limited information.

### Literature size

First, the bubble plots provide an overview of the research volume or quantity for the included topics in each priority area. For this estimate, we used the number of included RCTs per review, selecting the systematic review with the most included acupuncture RCTs for the individual topic as the research volume estimate. Reviews vary in their inclusion criteria for study designs (for example whether or not they include observational studies) and providing the volume for a well-established research design such as RCT that is always likely to be included should provide a broad estimate. Furthermore, the number of RCTs should provide an indicator of the overall research volume sufficient for this map of the literature. A pilot test showed that an alternative method, cumulatively adding all studies included in reviews on a particular clinical indication to a database to determine the complete research pool, is immensely time consuming and not feasible for large-scale evidence maps. In the case of acupuncture research, hundreds of individual studies need to be cross-checked against dozens of reviews to prevent duplication, but the lack of unique study identifiers and differences in translation of study titles make such cross-checking impractical within the project timeframe and resources.

### Clinical effectiveness

Secondly, the bubble plots provide a broad estimate of the clinical effectiveness of acupuncture for each differentiated clinical indication. This estimate of clinical effectiveness should ideally be a continuous measure representing the summary effect size for the clinical indication. However, in trying to apply this display method to reviews of acupuncture, we were unable to use a continuous measure such as effect size. Because the studies included in individual reviews may overlap, results of reviews cannot be pooled across reviews and meta-analyses (included studies are not all independent units, and individual studies may be included in more than one review). In addition, different reviews use different summary measures, such as weighted mean differences, odds ratios, or relative risks to summarize treatment effects; individual reviews focused on a variety of different condition-specific continuous or categorical outcome measures (e.g., treatment response, Beck Depression Inventory, Hamilton Depression Rating Scale among hundreds of other measures); inclusion criteria for eligible RCTs differed across reviews; and the review authors' conclusions were often inconsistent across reviews. Therefore, for this application, the bubble plots simply differentiate the findings according to 4 categories: “evidence of no effect,” “unclear evidence,” “evidence of a potential positive effect,” and “evidence of a positive effect.”

The category “evidence of no effect” was used for research areas that provided evidence for no positive effect, that is to say reviews which showed that results in the control groups are equivocal or better than in the acupuncture group. The “unclear evidence” category was used for conflicting results across reviews that could not be resolved or for conflicting results within reviews with authors summarizing the evidence as inconclusive. The “evidence of a potential positive effect” category was used for those areas where reviews showed that all individual RCTs or the pooled effect across RCTs were positive, but the best available secondary evidence or all systematic reviews concluded that the evidence base was insufficient to draw firm conclusions despite the statistically significant positive treatment effect. For example, several systematic reviews produced pooled estimates of effects that were statistically significantly positive, yet the review authors judged the evidence insufficient due to limitations of the included trials. The final category, “evidence of a positive effect,” was used for clinical areas with evidence of a statistically significant positive effect of acupuncture and where authors of the best available secondary literature recommended the intervention without major concerns regarding the existing evidence.

For each clinical topic, all available systematic reviews and recently published trials were reviewed. Most emphasis was given to Cochrane reviews, individual patient data reviews, and the largest review or recent trial. For topics with narrative reviews without statistical meta-analysis, conflicting results across or within reviews that could be resolved by a synthesis including all relevant RCTs, and for areas where a recent large trial was identified that was not yet incorporated into existing reviews, a statistician checked whether studies could be pooled and performed a meta-analysis to determine the treatment effect. The reanalysis used the data documented in the systematic reviews; it was not feasible to obtain primary study data from several hundred RCTs included in existing reviews. In many cases, it was not possible to resolve the conflicting evidence. Furthermore, the bubble plots summarize dozens of clinical areas, of which each area is represented by up to 10 recent reviews, each review potentially summarizing a large number of individual research studies. Hence the clinical effectiveness category should not be construed as a definitive answer of the effectiveness but rather represents a broad overview, or trend, to broadly summarize the research field.

The effect determination focused on the effectiveness of acupuncture compared to that of “passive” control groups, such as a waiting list group, no treatment, placebo / sham acupuncture, prescription-free or provider-independent interventions, usual care not further specified, and treatments given to both RCT arms. As we discuss in the future research section, what constitutes a valid control group for acupuncture intervention studies is an area of controversy. For this broad map of the literature we did not favor one control modality over another and had to rely on the published reviews to differentiate or pool across passive comparators. In order to provide a coherent and easy-to-interpret bubble plot across individual topics, we did not include the comparative effectiveness of acupuncture, that is to say acupuncture compared to active comparators such as medication interventions (e.g., equivalence or superiority assessments for acupuncture versus antidepressants). Instead, identified comparative effectiveness results were summarized in the narrative synthesis.

### Confidence

Finally, our confidence in the effect for each clinical indicator is represented by the size of the corresponding bubble. By default, we categorized our level of confidence as “Medium”. We changed the confidence to “High” only if an effect was shown in a Cochrane review adhering to strict methodological criteria or in an IPD systematic review not subject to typical meta-analytic limitations, based on the assumption that both of these kinds of reviews represent stronger evidence than an average systematic review. We changed the confidence to “Low” if the reported treatment effect was based primarily on studies not indexed in the largest medical database PubMed (defined as more than 50% of relevant RCTs not indexed) based on the assumption that studies in journals and other outlets not indexed in PubMed are more likely to be of low quality than studies published in PubMed-indexed journals. This issue has been shown to be of particular relevance to the research area acupuncture.22,23

Given the large number of clinical topics, the large number of reviews, and the fact that some clinical topics were associated with up to 10 current systematic reviews from independent author groups, this assessment could take only very limited information into account.

## OTHER RESULTS

Results from comparative effectiveness reviews (ie, reviews comparing acupuncture to other active treatments) were summarized in a narrative synthesis for each of the domains.

Adverse events of acupuncture interventions were summarized in a narrative synthesis. For this broad overview we only included reviews addressing adverse events in the title or the abstract of the publication and thereby indicating that adverse events were one of the main research questions addressed by the review.

## FUTURE RESEARCH

We identified evidence gaps by documenting clinical indications for which there is conflicting evidence across identified reviews or where reviews concluded that the existing evidence base is insufficient to come to firm conclusions. In addition, we documented those topic areas for which systematic reviews exist, but for which the reviews did not identify relevant RCTs. For the non-priority areas we highlighted where research on acupuncture was available but there were only one or 2 systematic reviews published since 2005 to provide a current estimate of the evidence. Finally, we checked the literature for ongoing systematic reviews that may become available to summarize a topic area in the near future.

## TECHNICAL EXPERT PANEL

The technical expert panel (TEP] for the project included Dr. Stephen Ezeji-Okoye, VHA CO Field Advisory Committee on Complementary and Alternative Medicine; Laura Krejci, Associate Director Office of Patient Centered Care and Cultural Transformation; Dr. Edward Seunghoon Lee; Dr. Marc Goldstein; Dr. An-Fu Hsiao; and Dr. Walter Fricke.

## PEER REVIEW

A draft version of the deliverables was reviewed by technical experts, as well as clinical leadership. Reviewer comments were addressed in the final product and are documented in the appendix.