# FUTURE RESEARCH

We identified evidence gaps by highlighting inconclusive evidence across or within reviews or a lack of primary research according to identified reviews.

However, an overarching theme and source of heterogeneity in results appeared to be the selection of the comparator against which the treatment effects of acupuncture was compared. The bubble plots summarize data from all passive controlled RCTs to determine the effectiveness of acupuncture. Passive controls included no treatment, waiting list assignment, acupuncture as add-on treatment to a treatment plan received by both treatment groups, and placebo control such as sham acupuncture. Clinical effectiveness estimates may depend on the chosen comparator. In research studies, placebo controls are used to blind participants ensuring that treatment effect estimates are not biased. However, in acupuncture trials there are additional considerations.

Sham acupuncture may include needles inserted superficially rather than deep at non-acupoints nearby; true needling at points not thought to influence the desired outcome; acupuncture devices with needles that retract into the handle rather than penetrate the skin; the use of blunt devices to apply pressure without penetration (Streitberger placebo acupuncture); or non-needle approaches, such as deactivated electrical stimulation or detuned laser.17,213 The type of sham acupuncture may already be a source of heterogeneity among studies assessing the effectiveness of acupuncture. Several authors have suggested that a noninvasive placebo needle at acupoints, such as that used in the Streitberger method, and sham involving needle penetration at non-acupoints may both elicit physiological effects similar to those of acupressure; thus the “sham” acupuncture would be more similar to acupressure than a true control for acupuncture.47,214,215 Zheng et al (2012)213 argues that surface stimulation at acupoints, such as acupressure or transcutaneous electrostimulation, should be considered as the adjunctive treatment rather than as a control. Other authors have suggested that the specific acupoints are not as relevant as traditionally assumed216 and the recent IPD meta-analysis on chronic pain concluded that differences between true and sham acupuncture are relatively modest suggesting that factors in addition to the specific effects of needling are important contributors to the therapeutic effects of acupuncture.47

Future research is needed to help distinguish between the effectiveness and cost-effectiveness of acupuncture and sham acupuncture. If the explanation for the observation of little difference in effectiveness between true and sham acupuncture is that both true and sham acupuncture have positive effects, then the specific implication for the VA could be that there is no need for training in acupuncture and for VA to hire licensed acupuncturists, since the sham acupuncture could be performed by a technician with minimal training. The scientific debate is ongoing; a number of reviews highlight clear differences between sham and true acupuncture and counter arguments that sham interventions involving needle penetration result in large nonspecific effects.119,217,218 Nonetheless, there is currently no universal standard for what constitutes an appropriate method or procedure for a sham acupuncture control, and that this may contribute to the discrepancy between observed clinical effectiveness of acupuncture and the lack of rigorous research supporting these observations.217

Further sources of heterogeneity appeared to be the inclusion criteria across reviews and the electronic databases searched. Reviews published in the same year did not use the same study pool and newer reviews rarely included all studies included in previous reviews, therefore simply accumulating additional evidence. A number of authors have pointed to publication bias (“do certain countries produce only positive results?”)23 For this broad overview we could only flag the concern and highlight inconsistencies across reviews. A number of authors have summarized challenges in acupuncture research that may contribute to the apparent complexity of the research area.219-221

## FUTURE RESEARCH: PAIN DOMAIN

In the Pain domain, we had to conclude for a number of specific clinical indications that the evidence base is currently unclear and a systematic review stratifying by comparator and outcome is needed to determine the effectiveness and size of the treatment effect. Clinical indications included acupuncture for back pain, neck pain, surgery analgesia, postoperative pain, fibromyalgia, shoulder pain, and rheumatoid arthritis.

Although we classified chronic pain as one of the conditions for which acupuncture has evidence of a positive effect and high confidence, this conclusion is limited by the lack of a consistent signal of positive effect in the individual pain categories that must make up any “chronic pain” population. Back pain alone usually accounts for 50% or more of chronic pain patients, and therefore if acupuncture has a positive effect in chronic pain patients then one would expect acupuncture to have a positive effect in chronic low back pain patients. Yet, we did not identify a definitive evidence synthesis for acupuncture and back pain. Similarly, one of the next most common conditions within a population of chronic pain patients is neck pain, and yet again the best available evidence synthesis of the effectiveness of acupuncture for neck pain is not equally positive as it is for the area chronic pain. This review of reviews suggests the need for an additional systematic review to resolve the discrepancy.

Furthermore, a Cochrane review for endometriosis did not identify any placebo or sham controlled RCTs.65 One comparative effectiveness review noted that although exercise, spinal manipulation therapy, and acupuncture are widely used interventions in the treatment of chronic low back pain, no study comparing acupuncture head-to-head with the alternative treatments was identified.63 A large 2013 RCT including 501 participants diagnosed with primary dysmenorrhea concluded that traditional Chinese medicine pattern might affect acupoint-specific effects on pain, however, the main results of the trial are not published yet.222

## FUTURE RESEARCH: WELLNESS DOMAIN

In the Wellness-relevant domain, we concluded for a substantial number of specific clinical indications that the therapeutic effectiveness of acupuncture is unclear and further research is needed. Topics included acupuncture for cancer treatment adverse events, IBS, rhinitis, blood pressure, menopausal symptoms, premenstrual symptoms, gastrointestinal diseases, tinnitus, dry eye, xerostomia, exercise, quality of life, and erectile dysfunction. For some of the clinical indications the evidence base appeared to be unclear due to the lack of research studies. However, the evidence base for physical symptoms of cancer treatment associated adverse events was unclear despite a large number of research studies. Inconclusive results were potentially due to the diversity of reviewed outcomes. Future systematic reviews and/or future individual studies may determine whether acupuncture has a role in these clinical indications and for which clinical outcome.

## FUTURE RESEARCH: MENTAL HEALTH DOMAIN

In the smallest research domain, Mental Health, the effect of acupuncture on CFS and its role in the treatment of addiction, in particularly opiate addiction, remained unclear. Systematic reviews should to differentiate effects on relapse rates and effects on drug withdrawal symptoms.

## FUTURE RESEARCH: OTHER INDICATIONS

In the Other Indication domain there were a number of clinical indications with only one or 2 reviews published in recent years. Topics included acupuncture for chemotherapy-induced leukopenia,196 Bell's Palsy,64,223 brain injury,28,70 asthma,79,160 epilepsy,131 breech presentation,115,139 facial spasm,198 angina pectoris therapy,34 spinal cord injury,32 Parkinson's disease,135 induction of labor,100 Alzheimer's disease,107 uremic pruritus,66 Meniere's syndrome,106 and the use of acupuncture in emergency departments.36

A Cochrane review on acupuncture for vascular dementia,150 assessed as up to date in April 2011, identified no randomized placebo-controlled trial that could inform the review question. Acupuncture for glaucoma was targeted in a 2009 Cochrane review145 but the review did not identify any RCT meeting inclusion criteria. A Cochrane review last updated in 2010 did not identify any RCTs on acupuncture for uterine fibroids.95 Pressure ulcers were addressed in a 2012 publication but no acupuncture study meeting inclusion criteria was identified.56 A 2010 review on polycystic ovarian syndrome did not identify any relevant RCTs.91

A couple of systematic reviews on broad topics such as sham acupuncture compared to true acupuncture exist but could not be considered in this review of reviews due to insufficient reporting and the lack of a sufficient number of relevant systematic reviews.114,128,137

Finally, the reviewed topics acupuncture for stroke rehabilitation and the role of acupuncture in supporting fertility treatment both had to be classified as unclear despite the large number of existing primary studies and systematic reviews.