# BACKGROUND

Many Veterans desire complementary and alternative medicine or integrative medicine modalities such as acupuncture, both for treatment and for the promotion of wellness. However, the effectiveness and adverse events associated with acupuncture are not firmly established. Given the VA's desire to promote evidence-based practice, this evidence mapping project will help provide guidance to VA leadership about the distribution of evidence to inform policy and clinical decision making.

In general, acupuncture is the stimulation of specific acupuncture points through penetration of the skin with needles, which aims to correct imbalances in the flow of qi, a concept of energy in traditional Chinese medicine (TCM), through meridians (ie, energy channels). The available published literature on acupuncture is extensive. PubMed searches in 2013 identified almost 20,000 citations with the term “acupuncture” and almost 1,500 randomized controlled trials (RCTs) with “acupuncture” in the title. Not surprisingly, a large number of systematic reviews and meta-analyses have been published to-date, and even a number of “reviews of reviews” are available in the published literature on acupuncture in general1-6 or for a specific clinical condition.4,7-20

Results from existing reviews of reviews about the effectiveness of acupuncture are non-conclusive. A systematic review of systematic reviews of acupuncture published between 1996 and 2005 included 35 reviews.1 The overview noted that 12 reviews reported support for acupuncture and 6 reported strong support; however, when applying strict inclusion criteria, such as randomized and double blind studies, good evidence of no benefit was shown. In 2007, Adams compiled a “Brief Overview - A summary of the evidence for use of acupuncture from systematic reviews and meta-analyses” for the Veterans Health Administration Office of Patient Care Services Technology Assessment Program.21 The report included 42 systematic reviews published since 2002 and concluded that higher quality studies are only beginning to emerge, the evidence base is heterogeneous, and the review results highlight the overall poor quality of studies and reporting. Thus, it is timely to assess the current state of reviews of acupuncture.

## KEY QUESTIONS/SCOPE OF PROJECT

The project deliverables are:

- An evidence map that provides a visual overview of the distribution of evidence (both what is known and where there is little or no evidence base) for acupuncture; and
- A set of executive summaries that would help stakeholders interpret the state of the evidence to inform policy and clinical decision making.

This project maps the literature for the indications Pain, Mental Health and Wellness; as well as any clinical area for which at least 3 reviews and/or recent large RCTs exist.