# PEER REVIEW COMMENTS/AUTHOR RESPONSES

Comment | Response
The scope here states that acupuncture is “one type of Traditional Chinese Medicine” (TCM). In fact, acupuncture is one aspect of Chinese or Oriental Medicine, (which includes multiple modalities including herbal medicine, manual therapies, and movement therapies) and TCM is school of thought in Chinese Medicine. There are other schools of thought as well. Acupuncture is practiced by practitioners of traditional Japanese Medicine as well as practitioners of Medical Acupuncture. | We have revised the sentence accordingly.
paragraph 1 The reviewers use the terms “effectiveness and harms” in …. this biases the reader toward negative bias. The usual terms are risk and benefit. | We have replaced the term “harms” with the broader, more accurate, and more common term “adverse events” to avoid any notion of bias.
page 4: Bubble Plots Review methods described on page 4 are somewhat difficult to follow. I would suggest editing for clarification. | The section has been edited for clarity and revised accordingly.
Reasoning for confidence of effect seems somewhat arbitrary. I am not sure that rating a systematic review low based only on the included studies not being indexed in PubMed is the best indicator available for assessing quality of evidence, although I do understand the reasoning. | With hundreds of reviews and RCTs we needed a simple system and used an issue that was both widely discussed as well as easy to follow up. We have added more references addressing the use of publically available studies in acupuncture research to provide more information on the rationale.
Also, it is unclear how the investigators controlled for the same RCTs being included in multiple SRs, as this could potentially alter the strength of the effect size. | For evidence maps we rely on the systematic reviews as published and have no control over the inclusion criteria of the review. To address this point, we have added a note following each of the three evidence maps and the limitation section alerting the reader to this issue.
Pg 6 ln 32 title should be VHA CO Field Advisory Committee. | changed
Pg12 ln 35 back pain is listed as unclear, yet included in part of positive effect seen in chronic pain. Is there a distinction between acute back pain and chronic back pain which would account for this? Given that back pain is the leading cause of chronic pain it seems surprising the evidence would be so different for back pain and chronic pain. | We have added a comparison of the studies included in the IPD review on chronic pain and the back pain, neck pain, headache, and osteoarthritis reviews. We have also highlighted issues surrounding the unique scope of reviews and the overlap of reviewed studies across reviews in each of the evidence maps and in the limitation section of the report.
In one of the reviews on the use of acupuncture for opioid addiction (page 22), which was not incorporated in the bubble plot, the issue of comparative effectiveness studies is raised – the conclusion was that acupuncture was no better than other treatment, but non-inferiority could be considered a positive finding. | To address this point, we have added a sentence to the limitation section of the report clarifying that an assessment of acupuncture need to take the clinical efficacy but also risks and benefits compared to standard treatment into account.
Pg 28 ln 2-3 and 20-21 in discussion on further research the evidence base is listed as unclear. With trend to positive in pain and wellness as well as some findings of positive evidence in pain it would have seemed that at least for the indications where the evidence is positive a more definitive statement than the evidence is unclear could have been made. | To address the point, we have specified in the future research section that the unclear evidence refers to specific clinical indications within the domains, not the domains itself.
When this report is made public services and facilities will be trying to determine what conditions have sufficient research to support their use. Those conditions with positive findings would appear to be conditions where use would be justified while those trending towards positive it could be considered. However, by reporting that the evidence base is unclear it would make all use seem questionable. It may be that policy will need to be written on how to use these findings and it may be that such guidance would be better than having each facility interpret the data individually. If there were any trends on patterns of usage both in frequency and duration of treatment that were seen that would be useful information for the field | We have moved the limitation section to the end of the report and stated more clearly that the evidence maps are not designed to give definitive answers regarding the effectiveness of acupuncture. We have made more explicit that we did not review the evidence base ourselves with standard methods, i.e. a systematic review; we only estimated the effectiveness of acupuncture judging from published reviews and recent trials. Consequently the evidence map is only meant as a broad overview over the evidence base indicating in which areas research has been conducted and we broadly summarized the results of the 184 included reviews.
Ernst E, White AR: A review of problems in clinical acupuncture research. Am J Chin Med 1997; 25(1):3-11 | We have cited the paper illustrating the complexity of the research area in the Future Research study.
Acupuncture trials are frequently inconclusive. Although the gold standard in clinical research is the double- blinded, placebo- controlled trial, yet this was designed to evaluate pharmaceuticals and not acupuncture, which includes and operator and individualization of treatment. One article concludes that “Problems in clinical acupuncture research include the diversity of forms of therapy, need for individualization, blinding and control procedures. “ (see above- Ernst E, White : Am J Chin Med 1997; 25(1):3-11) . Because our research methods are not yet adequate, it is important to consider supporting veteran demand at the same time sponsoring research activity in order to clarify the issues. | We agree, however the issue about supporting veteran demands while at the same time sponsoring research is a decision for VA policy makers.
I would suggest writing a set of “take home points” for each of the medical indications for which acupuncture was assessed. That is, using plain language, briefly describe the indications for which the VA should offer acupuncture to patients and which indications need further study. | We have added a summary to the report and clarified that guidance on how acupuncture should be offered within the VA is outside the scope of the evidence map.
Assessment needs to be done that can assess overall value of acupuncture taking into account multiple factors: clinical efficacy, cost savings, patient satisfaction, risk vs benefit compared to standard treatment for a particular clinical diagnosis. Most acupuncture studies look at clinical efficacy only. | We have added this point to the limitation section.
The bias is simply that the review sets randomized, placebo-control trials as the gold standard, when there are multiple issues with using placebo for acupuncture studies. Simply stating that there is no significant difference between sham and true acupuncture obscures the possibility that both sham and true acupuncture actually had positive effects. The effects of both should be reported. | For this reason we have not limited the evidence map to reviews of placebo-controlled trials and instead have focused on reviews on all passive-controlled comparators, including no control treatment, waiting lists, and add-on trials where acupuncture was added to a common treatment in one group only while the control group received no additional treatment. We have added the choice of comparator issue to the limitation section to highlight that it adds to the complexity of the research area. Future research is needed to help distinguish between the effectiveness and cost-effectiveness of acupuncture and sham acupuncture. If the explanation for the observation of little difference in effectiveness between true and sham acupuncture is that both have positive effects, then it may be that there is no need for training in acupuncture and for VA to hire licensed acupuncturists, since the sham acupuncture could be performed by a technician with minimal training.
Furthermore, the use of standardized treatments for the treatment arm may not be the optimal treatment for any given patient. Traditional acupuncture involves tailoring treatments to a person based on several factors, apart from the conventional medical diagnosis. Not all patients with the same symptom are given the same Chinese medical diagnosis. Because of this, each patient may be treated with different points. | We have added this point to the Future Research section (see Ongoing Research).
I am concerned that the supposed lack of evidence for some indications would be used to set policy precluding using acupuncture for specific conditions. For instance, in my experience, carpal tunnel syndrome responds very well to acupuncture. I am curious about the data that they examined. I believe that a trial of treatment is always warranted, as the risks and benefits to the patient are much more favorable than more invasive interventions. | To address this point, we have added that this report was not designed to inform policies regarding the use of acupuncture or precluding acupuncture for specific conditions within the VA to the limitation section. We have added more information regarding the carpal tunnel review.