# ADVERSE EVENTS OF ACUPUNCTURE

We identified 6 systematic reviews summarizing adverse events of acupuncture. In addition, a number of effectiveness systematic reviews addressed adverse events in the title or the abstract of the publication, indicating that adverse events was one of the main research questions addressed by the review.

## REVIEWS OF ADVERSE EVENTS OF ACUPUNCTURE

All 6 independent systematic reviews on adverse events of acupuncture focused on case studies. Because no denominator was reported (number of patients exposed), it is not possible to determine rates of adverse events from these data. In addition, no control group data were available; hence the results are difficult to interpret. The first adverse event review searched Medline through 2011 for literature on vascular injuries caused by acupuncture and found 31 cases, 3 of which resulted in death.201 This was an update of a prior review, and included all the cases found in the prior review.212 A second review focused on cardiac tamponade caused by acupuncture, and searched Embase, Medline, AMED, CENTRAL and the Chinese Journal Full-Text Database through January 2010.^204^ Of the 26 cases of cardiac tamponade found in 17 articles, 14 deaths were reported. All fatal instances were deemed to have certain causality linking the deaths to acupuncture treatment. A further review searched 4 major Chinese databases through 2010 for literature on adverse events more generally and found 1,038 cases in 167 papers.202 An acupuncture-related adverse event was defined as any unfavorable and unintended sign, symptom, or disease that presents during or after treatment with acupuncture regardless of causal relationship, and adverse events were classified in one of 4 categories: syncope (N=468), organ or tissue injury (N=451), infection (N=38), and others (N=81). Deaths were reported for 35 cases: 21 of 26 organ or tissue injury-related deaths were judged as having a “certain” likelihood of causality by 2 reviewers, and 3 of the 9 infection-related deaths were judged as certain. One review on acupuncture, moxibustion, and cupping searched 6 databases for English language case reports to 2011.^200^ Of the 117 reports published since 2000, 103 reports including 294 cases were related to acupuncture. Adverse events were categorized as either complications, including infections or organ or tissue injury, or adverse reactions. Three deaths were reported with case analysis supporting the causal link between the acupuncture treatment and the fatal outcome. A review that focused on the safety of acupuncture for osteoarthritis of the knee searched PubMed and a Japanese literature database through 2006 and found 12 relevant RCTs, of which 7 included adverse event information.205 This review found no serious adverse events. A final review of Chinese language literature on acupuncture-related adverse events searched 3 Chinese databases through 2009 and included 115 articles that identified a total of 479 cases.203 Adverse events were categorized as traumatic, infectious and other, and although 14 deaths were reported, the category and causality were not specified for all these fatal cases. Reviews called for more standardized procedures, including adverse event reporting mechanisms, safe practice procedures, and acupuncturist's qualifications and training, and warned that although adverse events are rare occurrences, a lack of regular reporting makes establishing a frequency difficult.

### Adverse Events in Reviews on Acupuncture for Pain

In the domain relating to Pain, 12 reviews addressed adverse events. One review of 10 RCTs of acupuncture for pain relief in labor found no events in the 6 trials that reported on adverse events.85 The other 11 reviews all found low rates of adverse event reporting, and of those reported, all events were minor symptoms such as bruising, nausea, temporary pain, dizziness or faintness, or discomfort.30,50,62,88,94,97,121,140,143,167,182 Three reviews noted that these symptoms were comparable to control groups,94,97,167 and one review of acupuncture for migraine prophylaxis found that acupuncture resulted in fewer adverse events than prophylactic drug treatment.121

### Adverse Events in Reviews on Acupuncture for Wellness

Thirteen reviews in the Wellness-relevant domain focused on adverse events as well as the clinical effectiveness. Three reviews on acupuncture treatment for insomnia found low rates of reporting of adverse events, and of the few reports, all but one event were minor events such as bruising.24,46,112 One instance of a patient dropping out of a study due to pain associated with acupuncture was reported by 2 of the reviews.46,112 The rest of the reviews in the wellness-relevant category also found low rates of adverse event reporting, and of those events that were reported, the events were minor such as temporary pain, nausea, dizziness, discomfort, or bruising.52,60,68,86,102,109,111,122,130,142

### Adverse Events in Reviews on Acupuncture for Mental Health

Of the Mental Health reviews, 6 focused on adverse events.96,103,110,162,164,179 Three reviews of alcohol dependence110, cocaine dependence162, and drug addiction179 found low levels of adverse event reporting (3 of 11 studies, 0 of 7 studies, and 5 of 8 RCTs, respectively), and those studies that did report adverse events mentioned mild levels of symptoms such as pain, bleeding, nausea and dizziness. Two reviews of depression mentioned adverse events. The first included 30 studies, of which one reported on adverse events, and found no statistical difference between acupuncture and the control group.96 The second review found 21 of the 35 included studies reported on adverse events, and in a pooled analysis acupuncture (including both active and sham) had a statistically significantly lower incidence of adverse events when compared to anti-depressants (10.2% vs 40.4%; P<0.001).103 The final review was of acupuncture for schizophrenia, and of the 5 trials included, 2 small trials reported on adverse events and found favorable results for acupuncture, both when used alone in comparison to antipsychotics and when used in combination with antipsychotics compared to antipsychotics alone.164

### Adverse Events in Reviews on Acupuncture for Other Indications

Four reviews in the Other Indication category were identified. Two small reviews including 5 and 8 studies of acupuncture for stroke found no included studies reported adverse events.41,157 A third review including 14 studies on acupuncture for acute stroke found 9 studies reported adverse events, the majority of which were minor.168 Of 386 cases, 6 were moderate to severe, with no mentions of fatal adverse events. Finally, a review of emergency department acupuncture adverse events found that 2 of the 4 included studies reported adverse events, but that all reports were minor (eg, bruising, dizziness).36