# SUMMARY AND DISCUSSION

## SUMMARY OF EVIDENCE BY KEY QUESTION

### Key Question #1 What definitions and measures of intervention success are used, and what evidence supports use of these definitions and measures?

In the studies we identified of management interventions to improve primary care access; the third next available appointment was the most commonly used measure of success. We identified no empiric data exist linking this choice to any health outcome. The next most commonly used measure of success was continuity, followed by patient satisfaction. Many publications that discuss access management do not include a definition of access.

### Key Question #2 What samples or populations of patients are studied, including eligibility criteria?

The patients who have been included in published studies of access management in primary care have not been described in detail. In general, though, they are likely typical of adult patients attending family medicine clinics, given that many patients came from similar contexts, except for the studies specific to VA.

### Key Question #3 What are the salient characteristics of local and organizational contexts studied?

Little is known about the local and organizational contexts of practice sites included in published studies of primary care access management interventions. Many sites were academically affiliated clinics, part of the British system, or in VA.

### Key Question #4 What are the key features of successful (and unsuccessful) interventions for organizational management of access?

All interventions were described by the authors as Advanced Access or Open Access, with 15 of the 19 studies including these phrases in the publication title. The most common intervention components were reducing the backlog of appointments, using fewer appointment types, and producing regular activity report.

### Key Question #5 Are relevant, tested tools, toolkits, or other detailed material available from successful organizational interventions?

We identified and retrieved 6 tools or guides for improving primary care access, 4 from settings linked to implementation studies: one from a VA setting, 2 from the IHI/Advanced Access group, and one from England. Two additional online tools came from Canada.

## LIMITATIONS

### Publication Bias

While data limitations prevent us from performing a statistical test of publication bias, such bias is almost certainly present, as less-than-successful implementations are unlikely to be written up for publication. Even successful implementations may not be written into reports or materials that would be identified by literature synthesis techniques, and these would also be missed in our process. Certainly there must have been more than the 17 implementations reported here of Advanced/Open Access, and we don't know anything about the contexts or success of these unpublished implementations. For instance, the Cleveland Clinic website states that the Clinic made 1.3 million same-day appointments in 2016, but no peer-reviewed evaluations of their program were found.^65^

### Study Quality

The quality of studies was variable. The main limitations were lack of a sufficient pre-intervention time period for the main outcome measure (to establish a baseline), and lack of reporting of intervention components and contexts.

### Heterogeneity

Nearly all studies reported dramatic improvements in the measure of wait time. Nevertheless, heterogeneity is difficult to determine because reporting of contexts and implementation components is poor.

Since contexts are poorly reported, most of the results are of uncertain applicability to the VA, with the exception of the 2 studies performed in VA.

## RESEARCH GAPS/FUTURE RESEARCH

The most important research gaps include better reporting of intervention components and contexts, longer period of follow-up time, and a systematic examination for other impacts of the primary care access management strategy on system outcomes other than the third next available appointment. As VA works to develop and field new measures for patient-reported access,^66^ understanding how these relate to system outcomes will also be important.

## CONCLUSIONS

There is a modest body of evidence about primary care access management strategies, but most of it is now more than 6 years old and all of it is about one particular strategy, Advanced/Open Access. Most studies report few contextual details, and reporting of intervention components is highly variable. The lack of substantial additional hypothesis-testing studies of the implementation of Advance/Open Access in the past 6 years is a marked contrast to the period 2003-2010, when 15 studies were reported, and suggests that something has shifted in the perception of Advanced/Open Access since 2010 or that practitioners doing work in this area may not be pursuing publications. If other primary care access management strategies exist, then they should be subject to hypothesis-testing studies.