# RESULTS

## LITERATURE FLOW

Our literature searches and expert recommendations identified 979 potentially relevant citations, of which 132 were included by the reviewer at the title screening. Of these, 108 abstracts were included and obtained as full-text publications. A total of 53 publications met all eligibility criteria. The 55 excluded studies from the full-text review were excluded for the following reasons: 10 were not evaluations and did not provide data for our synthesis; 6 did not discuss access management; 2 addressed access concerns outside the primary care appointment context; 6 were about a specific population; 11 did not include outcomes of interest; 8 were only relevant as background information; 9 were not describing an intervention; 2 were not available; and one was duplicative of an included publication. See Figure 1 for the literature flow. Details of included studies are provided in the Evidence Table (Appendix D). A full list of studies excluded at full-text review is included in Appendix E.

Figure 1 Literature Flow Chart

* Search results were from PubMed (n = 796), CINAHL (n = 103), and experts (n = 80)

** Manuscript reference list includes additional references cited for background and methods plus websites relevant to key questions.

### Description of the Evidence

We identified 53 articles that described access management in primary care, 13 articles that discussed metrics,^2,7-18^ 29 articles that described 19 interventions to improve access in primary care using management strategies,^19-47^ 6 toolkits or tools,^48-53^ and 5 additional includes that did not directly relate to a key question.^54-58^

#### Quality of Intervention Studies

Of the 19 intervention studies included, none met all the QI-MQCS quality criteria (see Table 1). One study met 14 of the 15 potential criteria,^42^ 3 studies met 13 criteria,^30,40,45^ 2 studies met 12 criteria,^22,29^ 4 studies met 11 criteria,^19,26,28,46^ one study met 10 criteria,^47^ and 8 studies met 9 criteria.^20,21,25,31,32,35,36,43^

Table 1 Quality Scores for Intervention Studies

Author, Year | Organizational Motive | Intervention Rationale | Intervention Description | Organizational Characteristics | Implementation | Study Design | Comparator | Data Source | Timing | Adherence | Org Readiness | Reach | Sustainability | Spread | Limitations
Radel, 2001^35^ | 0 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 0 | 0 | 1 | 0 | 1 | 0
Kennedy, 2003^26^ | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 0
Meyers, 2003^30^ | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0
Belardi, 2004^20^ | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 0 | 0 | 1
Solberg, 2004^42^ | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 0 | 1 | 1
Armstrong, 2006 ^19^ | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 0 | 1 | 1 | 0 | 0 | 1
Parente, 2005^31^ | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 1
Boushon, 2006^22^ | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1
Steinbauer, 2006^46^ | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 0 | 1 | 0 | 0
Rohrer, 2007^36^ | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 1
Mehrotra, 2008^29^ | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 1
Sampson, 2008^40^ | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | N/A | N/A | 1
Bennett, 2009^21^ | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 0 | 0 | 0 | 0
Phan, 2009^32^ | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 0 | 1 | 0 | 0 | 0 | 1
Tantau, 2009^43^ | 0 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 0 | 0 | 0
Cameron, 2010^45^ | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 0 | 1
Tseng, 2015^47^ | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 1 | 0 | 0
MacCarthy, 2012^28^ | 1 | 1 | 1 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 0
Harris, 2015^25^ | 1 | 1 | 1 | 0 | 1 | 1 | 0 | 1 | 1 | 0 | 0 | 1 | 0 | 0 | 1

0 = not reported; 1 = reported

All 17 studies met the 5 criterion relating to reporting of intervention rationale, intervention description, study design, data source, and timing. Fifteen studies met the criterion for describing organizational characteristics, 16 studies met the criterion relating to implementation description, 13 studies met the criterion for describing the comparator, 14 studies met the criterion for describing organizational motive, 11 studies met the criterion for reporting study limitations, 10 studies met the criteria for describing adherence, 9 studies met the criteria for describing organizational readiness, 10 studies met the criterion for reporting reach, 6 studies met the criterion for reporting sustainability, and 4 studies met the criterion for reporting on spread.

## KEY QUESTION 1 What definitions and measures of intervention success are used, and what evidence supports use of these definitions and measures?

We identified 53 publications about access management (see Evidence Table, Appendix D). Of these, 29 publications were related to 19 studies of interventions to improve access. Of these 19 studies, the most often used measure of intervention success was the third next available appointment in 14 studies; continuity in 7 studies; patient satisfaction in 3 studies; the wait time for the next available appointment in 5 studies; utilization in 2 studies; primary care physician access or visits in 3 studies each; and no-show rates in one study. No study reported using waiting times for newly enrolled patients as a measure. Studies could have more than one measure of access intervention success. Thus, in studies of interventions the most commonly used measure of success is the third next available appointment.

### Third Next Available Appointment

Of the 14 studies that used this measure of success, 7 studies cited evidence in support of it. The first study said using the third next available appointment was desirable because it was “thought to be more stable” than other choices like the next available appointment.^29^ This study cited 2 references in support of this. The first reference is a commentary where Mark Murray and Donald Berwick discussed the intervention called Advanced Access as a means for reducing waiting times and delays in primary care.^13^ This commentary includes a box of “Evaluation and Monitoring Measures for Advanced Access,” and included in this box is the “third next available appointment,” with the following text:

This statistic is used to measure the number of days a patient has to wait to get an appointment. The third appointment is featured because the first and second available appointments may reflect openings created by patients canceling appointments and thus does not accurately measure true accessibility.

Another study, by the same Advanced Access group, described third next available as an “anchor metric for Advanced Access [because it] more reliably reflects when the schedule actually has substantial capacity.”^43^ Two other studies describe similar reasoning, without use of any citations.^38,42^

The second reference in support of this measure was a description about how to implement Open Access by Boelke, Boushon, and Isensee.^9^ This article includes “Five Key Measures” associated with open access, one of which is the third next available appointment. This measure is chosen, “rather than the first or second, because it provides a more accurate picture of true backlog”.

Two studies citing a reference for the use of the third next available appointment referenced a working document from the Institute for Healthcare Improvement (IHI),^21,45^ while a third mentioned the IHI without a specific citation.^22^

Descriptions of how the third next available measure was calculated varied, with 8 of the studies using this measure reporting some information on their measurement technique (see Appendix F). Most of these descriptions lacked detail, aside from usually calculating a monthly measure from individual provider-level data. There were 2 studies that did provider richer descriptions. The first that included a detailed description discussed weighting based on provider work schedule and other scheduling considerations, as well as data collection considerations like collecting at consistent time and day.^29^ The other described using a “simulated patient” method where researchers called and attempted to make appointments with primary care providers.^38^ These “secret shopper”-style calls targeted both appointments with a particular randomly selected provider as well as with any doctor. One study used self-reported estimates.^28^

### Continuity

Two studies used pre-existing indices to measure continuity.^32,38^ Other measures of continuity were used without any justification, and include: percentage of patients assigned to a primary care provider who were seen by that provider,^30^ percentage of patient visits with primary care provider,^20,21^ patients responding “yes” on a survey when asked if they were able to see the provider they ideally wanted to see,^39^ or patient continuity by team.^47^

While none of these studies describe justifications, there are numerous studies linking continuity to health outcomes, or other relevant process outcomes.^7,16^ A recent evidence summary from July 2016 found 112 studies relating continuity with outcomes relevant to primary care.^16^ Of the 14 studies looking specifically at health outcomes, 11 studies showed positive results. All 10 studies of mortality showed reduced mortality with better continuity. When considering the effect of continuity on other process of care measures, this summary found positive results for utilization, care quality, preventive care use, adherence, cost savings, and patient satisfaction. Another recent study found an association between higher continuity of care and fewer hospital admissions,^7^ particularly for heavy users. However, it is a challenge to take a concept like “continuity” and turn it into an operational measure of access to assess interventions.

Continuity may also be an important balancing measure to access, and has been shown to be valued by patients when trade-offs between continuity and access were tested.^17^ In a discrete choice experiment in England, respondents preferred to wait longer to see a provider with whom they had continuity. This was true for minor conditions as well as for new conditions about which they were less certain, however the preferred wait was longer for the new condition (0.9 versus 2.4 additional days for relational continuity and 1.6 versus 7.8 days for informational continuity, respectively).

### Patient Satisfaction

VA uses 4 measures in their Survey of Healthcare Experiences of Patients (SHEP) as measures of access (each with response options of never, sometimes, usually, always):

1. In the last 6 months, when you contacted this provider's office to get an appointment for care you needed right away, how often did you get an appointment as soon as you needed? (primary care)
2. In the last 6 months, when you made an appointment for a check-up or routine care with this provider, how often did you get an appointment as soon as you needed? (primary care)
3. In the last 6 months, when you contacted this provider's office to get an appointment for care you needed right away, how often did you get an appointment as soon as you needed? (specialty care)
4. In the last 6 months, when you made an appointment for a check-up or routine care with this provider, how often did you get an appointment as soon as you needed? (specialty care)

We did not identify any studies assessing the relationship of these SHEP measures with other health outcomes. However, the Consumer Assessment of Health Plans survey (CAHPS) contains composite scores based on questions very similar to the types of questions used by VA to measure access. Experts with the CAHPS group identified 2 articles testing the relationships between these composite scores and outcomes including utilization and quality of care.^2,10^ One study focusing on pediatric emergency department use found that patients' ability to get primary care without long waits was statistically significantly associated with decreased odds of nonurgent emergency department use (OR: 0.48; 95% CI: 0.32-0.72).^10^ In the second study, Medicare enrollees' clinical quality of care was measured using 6 measures from the Medicare Health Plan Employer Data and Information Set (HEDIS).^2^ Five CAHPS composite measures, including the “getting care quickly” composite that is analogous to VA measures, were included in analyses. The “getting care quickly” composite was positively correlated with the quality of care measures for mammography and follow-up within 30 days after hospitalization for mental illness, but the composite was not found to be statistically significant in multivariate analyses when adjusting for the other composite scores and primary care factors.

Aside from its relationship with health outcomes, patient satisfaction has inherent value as an outcome itself, and is considered an important indicator of patient-centered care dimensions like engagement and loyalty.^11^

### Other Metrics and Definitions

In addition to these 19 studies of primary care access management interventions, we also identified 9 studies about primary care access management that included a definition of “access.” Of these nine, 3 studies used the third next available appointment,^12,15,18^ 3 studies used continuity,^18,54,55^ and 4 studies used other or aspirational definitions of access.^8,53,56,59^

Other definitions of “access” have not been supported with any evidence; in general, they are not supported at all. In 2 cases, proposed definitions were supported as being compatible with “the triple aim” or simply as being “operational measures important for primary care.”

In August 2014, the Evidence-based Synthesis Program Coordinating Center produced a memo on the evidence base for wait times. It concluded that “no studies have evaluated the effect of wait time targets on health outcomes in the VA system or anywhere else.”^14^

### Summary of Findings

In the studies we identified of management interventions to improve primary care access, the third next available appointment was the most commonly used measure of success. We identified no empiric data exist linking this choice to any health outcome. The next most commonly used measure of success was continuity, followed by patient satisfaction. Many publications that discuss access management do not include a definition of access.

### Quality of Evidence for Key Question 1

The quality of evidence supporting the use of the third next available appointment as a measure of success for primary care access management interventions is Insufficient due to the absence of studies assessing its association with health outcomes. However, it is the most widely used measure across systems and across countries.

## KEY QUESTION 2 What samples or populations of patients are studied, including eligibility criteria?

In the 19 studies of primary care access management interventions, the patients being studied were those at an academic family medicine practice in 7 studies (at Oregon,^47^ Halifax,^45^ Baylor,^46^ South Carolina,^21^ Pennsylvania,^20^ Phoenix,^32^ and Colorado^26^), patients attending family medicine clinics at 4 different Mayo Clinic locations,^36^ patients enrolled in 6 different clinics affiliated with Partners Community Health Care in Massachusetts,^29^ children in one pediatric practice,^31^ Veterans using the VA nationally,^19,27,41^ patients from 17 HealthPartners clinics in Minnesota,^42^ 1 military family medicine clinic,^30^ patients at 2 multisite organizations in Wisconsin and Rhode Island,^43^ patients seeing providers in Family Health Teams or Community Health Centers in Ontario,^25^ patients of primary care practices in British Columbia,^28^ and patients attending very large numbers of general practice clinics in England.^23,24,33,34,37-40,44^ One study did not provide information on the organizations or patients involved.^22^ No additional details of the patient populations were provided in the published studies of primary care access management interventions, with 2 exceptions,^21,25^ which presented standard demographic details of patients (see Evidence Table, Appendix D). In one study, the eligibility criteria specified patients had to be classified as “chronic-stable” according to the Adjusted Clinical Groups.^36^ No other study specified eligibility criteria.

The 3 VA studies describe the advanced clinic access initiative, in which the VA partnered with the IHI with the goal of building a system where patients are able to see their providers when they choose.^19,27,41^ Armstrong and colleagues describe the national scope of the initiative, with training collaboratives beginning in 1999.^19^ From April 2001 to April 2005, the average number of days until the next-available appointment in primary care fell steadily from 42.9 days to 15.7 days. The authors also present data from one VA health care system to provide a nuanced view of the implementation. This Amarillo case study shows a decline from January 2000 through September 2003 that fits the national trend, with a dramatic drop in days until the next available appointment after the initiation of the advanced clinic access, and barriers like a provider shortage increasing the days until the next available appointment.

The second study presents 3 strategies the VA used as part of the advanced clinic access initiative with case studies to illustrate how those strategies were applied.^41^ The strategies include shaping demand, matching supply and demand, and redesigning the system to increase supply. Of the 4 case studies included, 3 occurred outside of primary care and one described a primary care setting using panel management as a “match supply and demand” strategy. In this case study, primary care clinics in the Western New York area used target panel sizes of 1,200 active patients for physicians and 1,000 for nurse practitioners and physician assistants. They reduced average next-available appointment time from 44.9 days in January 2000 to 24.9 days in August 2002. During this time, the clinics also used the other 2 strategies, shaping demand and redesigning the system to increase supply.

The final study focuses on implementation and effectiveness of advanced clinic access at 78 medical centers in 2003.^27^ They conducted surveys and interviews to supplement administrative data to better understand the predictors of implementation. They found that implementation varied across sites, and that greater implementation was associated shorter wait times, and higher patient satisfaction in most areas for primary care.

One additional study described the same intervention, the advanced clinic access initiative, in a geriatrics clinic.^60^ Although not conducted in primary care, and therefore not eligible for inclusion in this review, this study found a decrease in the number of missed appointments, while there was no significant reduction in the number of patients seen.

### Summary of Findings

The patients who have been included in published studies of access management in primary care have not been described in detail. In general, though, they are likely typical of adult patients attending family medicine clinics, given that many patients came from similar contexts, except for the studies specific to VA.

### Quality of Evidence for Key Question 2

The quality of evidence for descriptions of the patients included for study in primary care access management interventions is Low. While not described in detail, they are likely typical of adult patients in family medicine clinics.

## KEY QUESTION 3 What are the salient characteristics of local and organizational contexts studied?

In the 19 identified studies of primary care access management interventions, the details of local and organizational contexts are very few. Six studies were at American academic medical center clinics,^20,21,26,32,46,47^ 9 references (all assessing the same intervention) came from a large-scale implementation of Advanced Access in English primary care,^23,24,33,34,37-40,44^ and 3 publications from the implementation of Advanced Care Access in the VA.^19,27,41^ Other details from various settings are in the Evidence Table (see Appendix D).

### Summary of Findings

Little is known about the local and organizational contexts of practice sites included in published studies of primary care access management interventions. Many sites were academically affiliated clinics, part of the British system, or in the VA.

### Quality of Evidence for Key Question 3

The quality of evidence for the local and organizational contexts of sites where primary case access management interventions have been implemented is Insufficient due to lack of description of context in the published studies.

## KEY QUESTION 4 What are the key features of successful (and unsuccessful) interventions for organizational management of access?

### Interventions Identified in the Literature

Of the 19 studies, all but 4 studies described the intervention of interest as Advanced Access or Open Access in the title of the publications. The 4 exceptions described studies of IHI initiatives, or implementations based on the IHI approach. They were described as the “Idealized Design of Clinical Office Practices”^35^, in which “open access policies” were implemented, a Virtual Breakthrough Series on “improving access and office efficiency in primary care,”^22^ in which IHI work included Advanced Access, a “Quality Improvement and Innovation Partnership… based on the Institute for Healthcare Improvement Breakthrough Series” which included a module on “advanced access,” and a “Practice Support Program… based on the Institute for Health Improvement Breakthrough structured learning series approach” which also included an “advanced access” module. Of note, nearly all of these studies of Advanced/Open Access were published between 2003-2010, and since then we identified only 3 additional studies of Advanced/Open Access.

#### Intervention Components

Although all studies were related to “Advanced Access” or Open Access”, and many referenced the original description by Murray & Tantau^61^ or the IHI initiative of Advanced Access, the reporting of the intervention components varied greatly among studies (see Table 2). Some studies reported no components at all, merely stating they had implemented Advanced (or Open) Access, while one study reported as many as 10 components.^29^

Table 2 Components of Interventions Reported in Included Studies

| Kennedy, 2003^26^ | Meyers, 2003^30^ | Belardi, 2004^20^ | Solberg, 2004^42^ | VA ^19^ | Steinbauer, 2006^46^ | Mehrotra, 2008^29^ | NHS^23,24,40^*** | Phan, 2009^32^ | Cameron, 2010^45^ | Tseng, 2015^47^
Original Murray and Tantau Components
Reduce backlog with extra hours, hold on new patients, extending return visit interval, or temporary staff | N^**^ | X | X | X | X | | X | X | | N^**^
Use fewer appointment types | | X | X | X | X | X | X | | X | | X
Develop contingency plans
Make arrangements for overflow capacity or provider leave | | X | | | X | | X
Add physician financial incentives for overflow capacity | | | | | | X
Reduce demand for unnecessary visits
Create alternatives to clinic visit such as nurse clinics or nurse telephone follow up | | | X | | X
Measures to reduce follow-up | | | | | | | | X
Predict and anticipate patient needs | | | | | X
Other Components
Establish panel size | | X | | | X | | X | | | | X
Adjust provider schedules to meet predicted periods of peak demand
Most appointments available on Monday | | | | | | | | X
Goals and Reporting
Regular activity report | | X | | X | | X | X | X | | X | X
Set goals | | | | | | | | | | X | X
Education
Patient education/engagement | X | X | | | | | X | X | | X
Staff/provider education | X | X | | | | | X | | | X
Reminding patients of appointments | | | | | | X | X
Establish leadership/ QI team | | | | | | | X | X | | X | X
Other Miscellaneous Components
Establish “window” for appointments | | | | | | X | | | X | | X
Patient access to physician schedules | | | | | | X
Establish rules for provider leave | | X | | | | X | X
Establish over-ride for staff to pre-book same-day slots | | | | N^**^ | | | | | X | | X
Reconfigure telephone system to handle additional capacity or triage | | X | | | | N^**^ | | X
Redirect workload from physicians to other providers (nurse, medical assistants, etc.) | | | | | | | | X
Optimize rooms and equipment | | | | | X

* Eight references did not describe any components of their interventions, and are not included in this table as a result^21,22,25,28,31,35,36,43^

** N = these components were specifically reported not to be included for this particular intervention

*** because the sites had variety in components used, noted here are the components that had statistically significantly different uptake between the Advanced Access and control groups

In their original description, Murray & Tantau describe 4 “high leverage” points: Reducing backlog (eg, temporarily increasing pay or staffing to increase appointment supply in order to decrease the backlog), using fewer appointment types (eg, creating a small number of generic appointment types), developing a contingency plan for high demand times, and reducing demand for unnecessary visits. Intervention components targeting these were reported in 6, 8, 4, and 3 studies, respectively. Two studies specifically reported they did not reduce the backlog of patient appointments prior to implementing Advanced Access.

Other commonly reported intervention components were establishing a panel size, setting goals, producing regular activity reports, and provider/patient education. It is very likely that part of the variation between studies in intervention components is due to differences in reporting by article authors.

Murray and Tantau also describe Advanced Access as a philosophy of care where today's work is done today. Assessments of the components implemented in the included studies do not capture the degree to which this philosophy was adopted by the practices. Scheduling mechanisms may be features of Advanced Access, but the broader model is missed if the focus is solely on appointment slots or same-day appointment systems.^34,62^

### Duration of Intervention Data

Most studies reported short-term access outcomes (see Table 3).

Table 3 Studies of Interventions to Manage Primary Care Access

Author, Year Title | Study Design | Duration of Intervention Data | Main Outcome
Radel, 2001^35^ “Redesigning clinical office practices to improve performance levels in an individual practice association model HMO” | Time series | 1 year | Decrease in wait time for established patient office visit: Site A: 11 days to 2 days Site B: 59 days to 1 day (Site B hired extra staff)
Kennedy, 2003^26^ “Implementation of an open access scheduling system in a residency training program” | Time series | 5 months | Visit volume per FTE increase
Meyers, 2003^30^ “Changing business practices for appointing in military outpatient medical clinics: the case for a true “open access” appointment scheme for primary care” | Time series | 4 months | Time to third next available appointment decreased from 2.5 days to 1 day.
Belardi, 2004^20^ “A controlled trial of an advanced access appointment system in a residency family medicine center” | Controlled before-and-after | 12 months | Time to third next available appointment statistically significantly decreased from 21 days to 4-7 days in the intervention group, whereas it did not change in the control group.
Solberg, 2004^42^ “Key issues in transforming health care organizations for quality: the case of advanced access” | Pre-post | 2 years | Mean third next available appointment decreased from 17.8 to 9.6 to 4.2 to 3.9 days.
Armstrong, 2005^19^ “Reinventing Veterans Health Administration: focus on primary care” Schall, 2004^41^ “Improving patient access to the Veterans Health Administration's primary care and specialty clinics” Lukas, 2008^27^ “The Implementation and Effectiveness of Advanced Clinic Access” | Time series | Intervention phased in over 2 ½ years, plus 16 months follow-up | Days to next available appointment decreased from 42.9 to 15.7 days.
Parente, 2005^31^ “A pre-post comparison of service operational efficiency and patient satisfaction under open access scheduling” | Pre-post | ? 3 months post-implementation (timing uncertain) | Wait time for next available appointment decreased from 18.7 to 11.8 days.
Boushon, 2006^22^ “Using a virtual breakthrough series collaborative to improve access in primary care.” | Time series | 18 months | Time to third next-available fell from 23 days to 10 days (60% reduction) among participating sites.
Steinbauer, 2006^46^ “Implementing open-access scheduling in an academic practice.” | Pre-post | 2.5 years | Time to third next available appointment decreased from 17 to 1 day.
Rohrer, 2007^36^ “Impact of open-access scheduling on realized access” | Post-only controlled after | 1 year | Patients seen in open access clinics had inconsistent differences in primary care visit or screening visits compared to non-open access clinics.
Mehrotra, 2008^29^ “Implementing open-access scheduling of visits in primary care practices: a cautionary tale” | Time series | 2 years | Mean time to third next available appointment initially decreased from 21 to 8 days, but then increased from 8 to 11 days. Some practices were worse at 2 years compared to baseline. No-show rate stayed constant at 14 percent.
Harris, 2015^25^ “Impact of a quality improvement program on primary healthcare in Canada: A mixed-method evaluation” | Post-only controlled after | 2 years (no long term data analyzed) | Mean number of days in QIIP group was lower than the control group (5.3 versus 6.6) but this difference was not statistically significant.
MacCarthy, 2012^28^ “Improving primary care in British Columbia, Canada: evaluation of a peer-to-peer continuing education program for family physicians” | Pre-post | 8 weeks | Statistically significant decreases in urgent appointments (1.21 mean days less), regular appointments (3.34 mean days less), and third next available appoints (3.40 mean days less) were found comparing wait times before and after the advanced access learning module.
Sampson, 2008^40^ “Impact of same-day appointments on patient satisfaction with general practice appointment systems Pickin, 2004^33^ “Evaluation of advanced access in the national primary care collaborative” Windridge, 2004^44^ “Problems with a ‘target’ approach to access in primary care: a qualitative study” Dixon, 2006^23^ “Advanced access: more than just GP waiting times?” Goodall, 2006 ^24^ “Implementation of Advanced Access in general practice: postal survey of practices” Salisbury, 2007^37^ “Does Advanced Access improve access to primary health care? Questionnaire survey of patients” Salisbury, 2007^39^ “An evaluation of Advanced Access in general practice” Salisbury, 2007^38^ “Impact of Advanced Access on access, workload, and continuity: controlled before-and-after and simulated-patient study.” Pope, 2008^34^ “Improving access to primary care: 8 case studies of introducing Advanced Access in England.” | Time series | 1 to 3 years | Mean time to third next available appointment decreased from 3.6 to 1.9 days. Qualitative studies with patients indicated some dissatisfaction with being able to schedule an appointment on any day other than day of the telephone call.
Bennett, 2009^21^ “The effect of a carve-out advanced access scheduling system on no-show rates” | Time series | 14 months | Time to third next available appointment decreased from 30.7 to 9.0 days. No-show rate did not change (between 18-24 percent).
Phan, 2009^32^ “Decreased continuity in a residency clinic: a consequence of open access scheduling.” | Pre-post | 2 years (1 pre, 1 post) | Continuity worsened, with the Usual Provider Continuity Index (UPC) dropping from 0.59 to 0.55 (not statistically significant) and the Modified Modified Continuity Index (MMCI) decreasing from 0.51 to 0.44 (p=0.001).
Tantau, 2009^43^ “Accessing patient-centered care using the advanced access model.” | Time series | 7 months for appointment delays 20 months for no-show rate | Appointment delays at one site were reduced over 7 months from an average of 25 days to an average of 8 days. The no-show rate at another site fell from an average of 30 % to less than 15% over 20 months.
Cameron, 2010^45^ “Adoption of open-access scheduling in an academic family practice” | Time series | 9 months | Time to third next available appointment decreased from 13.7 to 3.6 days. No-show rate dropped from 3 percent to 2 percent.
Tseng, 2015^47^ “Implementation of advanced access in a family medicine residency practice” | Time series | ?2 months (timing uncertain) | Time to third next available appointment “trended down” from about 10-20 days to 1-10 days for different clinics.

#### Longer-duration Studies

We identified 8 studies reported access outcomes at more than one year after implementation.^19,21-23,29,32,42,46^ Two of these were the large implementations in the English National Health Service and VA. Three others were about implementation in single academic primary care practices. One article described the results of the use of a “virtual breakthrough series” on 17 health organizations, while a separate 17 clinics in Minnesota were described in another implementation. The last article was about implementation in 5 academically affiliated primary care practices in Massachusetts.

The implementation in Massachusetts was described by the authors as open access scheduling following the principles as described by Murray and Berwick and Murray and Tantau.^29^ All clinics studied were described as having “fully implemented” the intervention. The primary outcome was the time to the third next available appointment. Secondary outcomes were patient and staff satisfaction, and no-show rates. Within the first 4 months of implementation, the average time to the third next available appointment fell from 21 to 8 days for a “long” primary care visit, and from 39 to 14 days for a “short” primary care visit. However, thereafter in 4 of the 5 clinics waiting times rose, from 8 to 11 days for “long” visits and from 14 to 29 days for “short visits.” In 2 clinics, at 2 years the wait times were worse than before implementing open access. Among secondary outcomes, there was no change in the no-show rate or in patient satisfaction with access; however staff perception that access was “very good” or “excellent” increased from 35% to 39%. The authors speculate that their results were due to “unexpected barriers that prevented the practices from fully implementing the model”, which included extended provider leave, the difficulty in assessing appointment demand, and a lack of appropriate incentives to increase access.

In one of the 3 articles describing open access in single academic primary care practices, results were reported for 14 months.^21^ During this time period, the time for the third next available appointment dropped dramatically, from 31 to 9 days. Despite this, the proportion of no-show appointments did not change, being just under 20% before and after the implementation. The effect on continuity was minimal. These authors also speculated that the reason for lack of improvement on these other 2 outcomes was “we were not able to fully implement an advanced access model”. The second article assessing open access scheduling in a single academic primary care practice focused solely on continuity.^32^ Using 2 complex measures of continuity, the Usual Provider Continuity Index and the Modified Modified Continuity Index, over an 18-month period of time the authors reported finding decreases in both these indices (meaning worse continuity), and for the Modified Modified Continuity Index this was statistically significant (from 0.489 to 0.429, p reported as = 0.01). The authors attributed this to an increased number of visits by patients to clinicians other than their primary provider. The third article assessing open access scheduling in a single academic primary care clinic reported that the clinic has been able to keep its time to the third next available appointment at 1 day for 2.5 years. The authors also report no change in the no-show rate of 8%.^46^

In the article reporting on the use of the virtual breakthrough series, the authors report that of the 17 organizations that participated, at the end of one year 10 of these had “achieved significant improvement” (defined as being most components of the change packaged had been implemented, and there were improvements in the outcomes of the time to the third next available appointment and office visit cycle time), and that of these 7 had maintained or improved their gains an additional 6 months later.^22^

The large implementations in the English NHS and in VA were the subjects of numerous evaluations, and summarizing all the results succinctly is challenging. In general, both evaluations showed mixed results. The time to the third next available appointment did improve on average, but substantial proportions of clinic or sites struggled to implement the intervention: in the VA implementation only 32% to 42% of facilities were judged to have fully implemented advanced access in all their clinics;^27^ while in the NHS implementation only 66% of practices reported improvements in time to the third next available appointment; for 16% of practices this value was unchanged and in 16% of practices it worsened.^33^ The NHS implementation was also the subject a famous “law of unintended consequences” moment, where Prime Minister Tony Blair was made aware on live television of patients' unhappiness at being forced to make appointments for care only on the same day (and thus the practice would report that the wait time for a visit never exceeded 1 day). A published evaluation showed for every 10% increase in same-day appointments in a GP's practice there was an 8% decrease in the number of patients satisfied.^40^

### Study Designs Employed

There were no randomized controlled trials. One study used a controlled before-and-after design,^20^ while 2 others used a post-only with control group design.^25,36^ Five used a pre-post design, while the rest of the studies used a time series design, although there were usually few points before the implementation of the intervention sufficient to establish a baseline.

### Results from Included Studies

#### Wait Times

All studies measuring wait times reported some success, most commonly the time to the third next available appointment. Most studies had a pre-intervention value measured in 10-30 days, although 4 studies had pre-intervention or comparison group values that were 2.5 days,^30^3.6 days,^23^ 6.6 days,^25^ and 5.20 days,^28^ substantially better than the post-intervention values for most other studies. The magnitude of the effect in most studies was quite large: reductions in wait time of more than 50 percent. No study specifically looked at wait times for newly enrolled patients.

#### Continuity

Seven publications described the mixed effects of access management interventions on continuity of care.^20,21,30,32,38,39,47^ Three studies showed improvements in continuity,^20,21,30^ one study in a residency clinic found statistically significant decreases in 2 continuity indices,^32^ and 3 found no differences.^38,39,47^ Measures included the percentage or proportion of patient visits with the designated primary care provider, continuity indices, and patient survey data.

#### Other Outcomes

One study focused on visit volume per FTE, which increased over the 5 months it was measured.^26^

One study described perceived problems from a staff perspective.^34^ In qualitative interviews at 8 NHS practices, the 4 sites adopting Advanced Access described issues such as lower continuity. No studies assessed unanticipated negative consequences such as provider burnout and gaming, nor did they verify their measures relative to either gaming or inadvertent misrepresentation.

### Summary of Findings

All interventions were described by the authors as Advanced Access or Open Access, with 15 of the 19 studies including these phrases in the publication title. The most common intervention components were reducing the backlog of appointments, using fewer appointment types, and producing regular activity report.

### Quality of Evidence for Key Question 4

We judged the quality of evidence for intervention components as Low, due to heterogeneity across studies, the lack of published unsuccessful interventions to compare components, and the high likelihood of publication bias with respect to the reporting of components.

## KEY QUESTION 5 Are relevant, tested tools, toolkits, or other detailed material available from successful organizational interventions?

We identified a 2016 systematic review by Janamian and colleagues that identified online tools and resources to support organizational improvement in primary care.^50^ This systematic review scored 6 out of 11 using the AMSTAR quality criteria.^63^ The authors searched CINAHL, Embase, and PubMed from January 2004 through December 2013, as well as conducting a grey literature search for materials from as early as 1992. Their database search identified 1,900 records after duplicates were removed, which contributed 109 studies of 76 tools or resources meeting the inclusion criteria. The grey literature search identified an additional 186 tools or resources meeting the preliminary inclusion criteria. From both the database searches and grey literature, a combined 53 tools or resources scored highly on the appraisal of accessibility, relevance, utility, and comprehensiveness, and were considered part of the final set of tools and resources. We searched these 53 and identified 4 tools relevant to primary care access management, of which 2 were no longer available online.

The first tool we were able to retrieve is a 162-page guide, possibly designed for or influenced by the goal to improve access in NHS GP practices by the NHS Practice Management Network.^53^ The guide is divided into sections of the following: do you understand your demand?; managing and meeting demand; the practice environment; telephony; ensuring a patient-focused service; understanding your community; communications; patient engagement; and change. These sections include a series of step-by-step guides, case studies, and tips.

The second tool was available online, and was a website comprised of resources relating to VA's patient aligned care teams (PACT), a patient-centered medical home model.^64^ These resources include links to VA and non-VA materials, including: a patient-centered medical home concept paper; 10 things you can do now list; engaging your team: the first step towards shared innovation; make room for patient-centered care; analyze tasks for the patient-centered medical home; and useful non-VA website links.

In addition to these tools from the systematic review by Janamian and colleagues, we identified 4 tools from content experts.^48,49,51,52^ The first was a commentary describing the role of panel size in balancing the supply of appointments with patient demand, as well as how to calculate panel size and make adjustments.^52^ The other 3 tools provided resources like case studies, publications, details on how to calculate measures related to access, and information on key concepts relating to access (eg, mapping flow, creating contingency plans) on websites from the Institute for Healthcare Improvement,^49^ Health Quality Ontario's Advanced Access and Efficiency for Primary Care,^51^ and Alberta Access Improvement Measure group.^48^

### Summary of Findings

We identified and retrieved 5 tools or guides for improving primary care access, 4 from settings linked to implementation studies: one from a VA setting, 2 from the IHI/Advanced Access group, and one from England. One additional online tool came from Canada.

## ADDITIONAL RELEVANT LITERATURE

We identified 5 publications that did not fit as evidence in the Key Questions, but nevertheless seemed to provide information that is relevant, and are included in their own section here. Four of the publications were modeling studies, and therefore were not “interventions” and one publication was about how improved access was spread across Sweden. In addition to these included publications, 2 reports also merit discussion as background: a prior VA review on interventions to increase Veteran access, and a VA-sponsored Institute of Medicine report on improving access and wait times.

### Modeling Studies

One publication modeled what the “right patient panel size” is for primary care.^56^ This study was done in the context of advanced access, where the goal is for all patients desiring an appointment with a specific provider be accommodated by that provider on that day. This model starts with the observation that demand is not constant from day-to-day, and if the capacity is present to serve, say, exactly 10 patients a day, then a series of days that alternate between 9 and 11 patients requesting an appointment that day will inevitably lead to a growing backlog of patients. This is because the extra service capacity available on a day when only 9 patients seek care cannot be transferred to the next day and is therefore lost. These authors call “safety capacity” the amount of available capacity in excess of average demand, which acts as a buffer against variable increases in demand. The authors developed a model, and then present example panel sizes for primary care based on the existing number of daily slots and the desired “overflow frequency”, meaning the number of days the individual clinician would need to work extra in order to see all the patients, based on seeing patients all 5 days a week. For the situation where there are 20 daily appointment slots for a clinician, and the “overflow frequency” is set at 10% (meaning 1 out of every 10 days the clinician will need to work extra time to see all patients that day), then the formula calculates the panel size as 2053.

Another publication compared traditional scheduling with open-access scheduling performance under a variety of parameters.^57^ These included varying the no-show probability, expected workload, length of the workday, overtime surcharge, panel size, and whether a doctor must stay for the whole work day or leave after the last patient. Open-access scheduling outperformed the traditional scheduling approach almost all scenarios the model tested. The exception where traditional scheduling performed better was in the case where the no-show probability was set to less than 5 percent.

Two publications, with the same lead author, modeled how access and continuity could be improved. The first of these used actual data from Mayo clinics to model how re-allocating group practice patients could improve capacity. Patients were classified by age and gender into 28 different categories. By re-allocating patients such that case-mix is evenly distributed across clinicians in the group, wait times were decreased by 40% and continuity was increased by 40%.^54^ The second study by this author modeled when pre-scheduled appointments are best made within the day to achieve increases in access and continuity. Using actual data from a 3-provider family medicine clinic, the authors concluded that a design which clusters all pre-scheduled appointments into 2 blocks – one early in the morning, the other early in the afternoon – is the best in terms of access, continuity, and the ability to accommodate some patients that can only have morning or only have afternoon appointments. ^55^

### Spreading Improved Access across Sweden

We identified one article that was mostly about how the authors adapted the Institute for Healthcare Improvement Breakthrough model for advanced access and first improved access in one section of Sweden, and then successfully spread it nationwide.^58^ Details of the intervention at specific sites are not presented, rather the intervention is described as 4 “learning sessions” where teams from various clinics “focus on identifying their own access problems” and “analyze survey results,” “tell each other their own stories,” and “teach each other.” The article then describes the stepwise spread of the intervention to other counties in Sweden, with some variability in the results (approximately 20% of participating teams showed no improvement in access).

### “Interventions to Improve Veterans Access to Care: A Systematic Review of the Literature” (2011)

This review was conducted by the Minneapolis VA Evidence Synthesis Program.^27^ The Key Questions were;

Key Question 1. What is the evidence in Veterans' ability to obtain needed health care (ie, access) contributes to variation in system-level (eg, utilization, satisfaction) or patient-level (eg, quality of life, functional ability, mortality) outcomes?

Key Question 1A. Does the effect of access on system- and/ or patient-level outcomes differ by patient, treatment, or setting characteristics?

Key Question 2. What interventions have been successful in improving health care access for patient populations with reduced health care access?

Key Question 2A. Have interventions that improved health care access led to improvements in system-level and patient-level outcomes?

The authors searched multiple databases from 1990 to 2010, and identified 23 articles relevant to Key Question 1 and 26 articles relevant to Key Question 2. For Key Question 2, among the 26 articles there were 5 RCTs. Studies were categorized as the opening of Community Based Outpatient Clinics (6 articles), primary care mental health integration (6 articles), intensive case management (2 articles), use of telemedicine (4 articles), outreach (1 article), decreasing co-payments (4 articles), and 3 other articles outside this classification scheme. All articles reported an association between the intervention and at least one measure of access (actual, perceived, or satisfaction with access). Limitations of the evidence base were a paucity of well-controlled studies and that only 6 articles reported any patient-level outcomes.

### “Transforming Health Care Scheduling and Access” (2015)

This report from the Institute of Medicine (now the National Academies of Science, Engineering, and Medicine) was sponsored by VA.^4^ The charge was to assess the range of experiences nationally and to identify existing standard and best practices. Key findings of the report were that there is insufficient evidence to support any particular measure of access and timeliness, and that more work needs to be done to establish standardized measures. In Chapter 4, “Building from Best Practices,” with respect to primary care 2 “best practice” examples were presented: open access/same-day scheduling; and “the smoothing flow scheduling model.” The latter is presented with an example from Louisiana, with the citation of a New Orleans newspaper article. The general principle with respect to “scheduling practices… to minimize the number of appointment types in order to streamline patient visits” is a commentary that discusses this method primarily in the context of surgical procedure scheduling.