# REFERENCES

1 Institute of Medicine. Crossing the Quality Chasm: A New Health System for the 21st Century. Washington, DC: The National Academies Press; 2001.
2 Schneider EC, Zaslavsky AM, Landon BE, Lied TR, Sheingold S, Cleary PD. National quality monitoring of Medicare health plans: the relationship between enrollees' reports and the quality of clinical care. Med Care. 2001;39(12): 1313-1325.11717573
3 Kehle SM, Greer N, Rutks I, Wilt T. Interventions to improve veterans' access to care: a systematic review of the literature. Journal of General Internal Medicine. 2011;26(2):689.21989623
4 Institute of Medicine. Transforming Health Care Scheduling and Access: Getting to Now. Washington, DC: The National Academies Press; 2015.
5 Hempel S, Shekelle PG, Liu JL, . Development of the Quality Improvement Minimum Quality Criteria Set (QI-MQCS): a tool for critical appraisal of quality improvement intervention publications. BMJ Qual Saf. 2015;24(12):796-804.
6 GRADE working group. GRADE website. 2014; http://www.gradeworkinggroup.org/. Accessed 05/05/17.
7 Barker I, Steventon, A., & Deeny, S. R. Association between continuity of care in general practice and hospital admissions for ambulatory care sensitive conditions: cross sectional study of routinely collected, person level data. . BMJ Open. 2017;356(j84).
8 Berry LL, Beckham D, Dettman A, Mead R. Toward a strategy of patient-centered access to primary care. Paper presented at: Mayo Clinic Proceedings; 2014.
9 Boelke C, Boushon B, Isensee S. Achieving open access: the road to improved service & satisfaction. Med Group Manage J. 2000;47(5):58-62, 64-56, 68.
10 Brousseau DC, Bergholte J, Gorelick MH. The effect of prior interactions with a primary care provider on nonurgent pediatric emergency department use. Arch Pediatr Adolesc Med. 2004;158(1):78-82.14706963
11 Browne K, Roseman D, Shaller D, Edgman-Levitan S. Analysis & commentary measuring patient experience as a strategy for improving primary care. Health Affairs. 2010;29(5):921-925.20439881
12 Knight A, Lembke T. Appointments 101--how to shape a more effective appointment system. Aust Fam Physician. 2013;42(3): 152-156.23529528
13 Murray M, Berwick DM. Advanced access: reducing waiting and delays in primary care. JAMA. 2003;289(8): 1035-1040.12597760
14 Peterson K, McCleery E, Helfand M. Memo: An Evidence-based Wait Time Threshold. VA ESP Project #09-199. 2014.
15 Pierdon S, Charles T, McKinley K, Myers L. Implementing advanced access in a group practice network. Fam Pract Manag. 2004;11(5):35-38.
16 Top Alberta Doctors. Evidence Summary: The Benefits of Continuity in Primary Care. 2016; http://www.topalbertadoctors.org/file/top--evidence-summary--value-of-continuity.pdf Accessed 5/5/2017.
17 Turner D, Tarrant C, Windridge K, . Do patients value continuity of care in general practice? An investigation using stated preference discrete choice experiments. J Health Serv Res Policy. 2007;12(3): 132-137.17716414
18 Donahue KE, Reid A, Lefebvre A, Stanek M, Newton WP. Tackling the triple aim in primary care residencies: the I3 POP Collaborative. Fam Med. 2015;47(2):91-97.25646980
19 Armstrong B, Levesque O, Perlin JB, Rick C, Schectman G. Reinventing Veterans Health Administration: focus on primary care. J Healthc Manag. 2005;50(6):399-408; discussion 409.16370126
20 Belardi FG, Weir S, Craig FW. A controlled trial of an advanced access appointment system in a residency family medicine center. Fam Med. 2004;36(5):341-345.15129381
21 Bennett KJ, Baxley EG. The effect of a carve-out advanced access scheduling system on no-show rates. Fam Med. 2009;41(1):51-56.19132573
22 Boushon B, Provost L, Gagnon J, Carver P. Using a virtual breakthrough series collaborative to improve access in primary care. Jt Comm J Qual Patient Saf. 2006;32(10):573-584.17066995
23 Dixon S, Sampson FC, O'Cathain A, Pickin M. Advanced access: more than just GP waiting times? Fam Pract. 2006;23(2):233-239.16364952
24 Goodall S, Montgomery A, Banks J, Salisbury C, Sampson F, Pickin M. Implementation of Advanced Access in general practice: postal survey of practices. Br J Gen Pract. 2006;56(533):918-923.17132379
25 Harris SB, Green ME, Brown JB, . Impact of a quality improvement program on primary healthcare in Canada: A mixed-method evaluation. Health Policy. 2015;119(4):405-416.25476553
26 Kennedy JG, Hsu JT. Implementation of an open access scheduling system in a residency training program. Fam Med. 2003;35(9):666-670.14523666
27 Lukas CV, Meterko MM, Mohr D, Seibert MN. The Implementation and Effectiveness of Advanced Clinic Access. HSR&D Management Decision and Research Center: Department of Veterans Affairs; 2004.
28 MacCarthy D, Kallstrom L, Kadlec H, Hollander M. Improving primary care in British Columbia, Canada: evaluation of a peer-to-peer continuing education program for family physicians. BMC Medical Education. 2012;12(1):110.23140230
29 Mehrotra A, Keehl-Markowitz L, Ayanian JZ. Implementing open-access scheduling of visits in primary care practices: a cautionary tale. Ann Intern Med. 2008;148(12):915-922.18559842
30 Meyers ML. Changing business practices for appointing in military outpatient medical clinics: the case for a true “open access” appointment scheme for primary care. J Healthc Manag. 2003;48(2):125-139.12698613
31 Parente DH, Pinto MB, Barber JC. A pre-post comparison of service operational efficiency and patient satisfaction under open access scheduling. Health Care Manage Rev. 2005;30(3):220-228.16093888
32 Phan K, Brown SR. Decreased continuity in a residency clinic: a consequence of open access scheduling. Fam Med. 2009;41(1):46-50.19132572
33 Pickin M, O'Cathain A, Sampson FC, Dixon S. Evaluation of advanced access in the national primary care collaborative. Br J Gen Pract. 2004;54(502):334-340.15113514
34 Pope C, Banks J, Salisbury C, Lattimer V. Improving access to primary care: eight case studies of introducing Advanced Access in England. J Health Serv Res Policy. 2008;13(1):33-39.18325154
35 Radel SJ, Norman AM, Notaro JC, Horrigan DR. Redesigning clinical office practices to improve performance levels in an individual practice association model HMO. J Healthc Qual. 2001;23(2):11-15; quiz 15, 52.
36 Rohrer JE, Bernard M, Naessens J, Furst J, Kircher K, Adamson S. Impact of open-access scheduling on realized access. Health Serv Manage Res. 2007;20(2):134-139.17524225
37 Salisbury C, Goodall S, Montgomery AA, . Does Advanced Access improve access to primary health care? Questionnaire survey of patients. Br J Gen Pract. 2007;57(541):615-621.17688755
38 Salisbury C, Montgomery AA, Simons L, . Impact of Advanced Access on access, workload, and continuity: controlled before-and-after and simulated-patient study. Br J Gen Pract. 2007;57(541):608-614.17688754
39 Salisbury C B, J., Goodall S, Baxter H, . An evaluation of Advanced Access in general practice. National Co-ordinating Centre for NHS Service Delivery and Organisation 2007:306.
40 Sampson F, Pickin M, O'Cathain A, Goodall S, Salisbury C. Impact of same-day appointments on patient satisfaction with general practice appointment systems. Br J Gen Pract. 2008;58(554):641-643.18801282
41 Schall MW, Duffy T, Krishnamurthy A, . Improving patient access to the Veterans Health Administration's primary care and specialty clinics. Jt Comm J Qual Saf. 2004;30(8):415-423.15357131
42 Solberg LI, Hroscikoski MC, Sperl-Hillen JM, O'Connor PJ, Crabtree BF. Key issues in transforming health care organizations for quality: the case of advanced access. Jt Comm J Qual Saf. 2004;30(1):15-24.14738032
43 Tantau C. Accessing patient-centered care using the advanced access model. J Ambul Care Manage. 2009;32(1):32-43.19104292
44 Windridge K, Tarrant C, Freeman GK, Baker R, Boulton M, Low J. Problems with a ‘target’ approach to access in primary care: a qualitative study. Br J Gen Pract. 2004;54(502):364-366.15113520
45 Cameron S, Sadler L, Lawson B. Adoption of open-access scheduling in an academic family practice. Canadian Family Physician. 2010;56:906-911.20841595
46 Steinbauer JR, Korell K, Erdin J, Spann SJ. Implementing open-access scheduling in an academic practice. Fam Pract Manag. 2006;13(3):59-64.
47 Tseng A, Wiser E, Barclay E, Aiello K. Implementation of advanced access in a family medicine residency practice. J Med Pract Manage. 2015;31(2):74-77.26665471
48 Alberta Access Improvement Measure. Alberta Access Improvement Measure. http://www.albertaaim.ca/resourcespage.html. Accessed 12/21/2016.
49 Institute for Healthcare Improvement. Resources. 2017; http://www.ihi.org/resources/Pages/default.aspx. Accessed 01/23/2017.
50 Janamian T, Upham SJ, Crossland L, Jackson CL. Quality tools and resources to support organisational improvement integral to highquality primary care: a systematic review of published and grey literature. Med J Aust. 2016;204(7 Suppl):S22-S28.27078788
51 machealth. Advanced Access and Efficiency for Primary Care. 2015; https://machealth.ca/programs/advanced-access-efficiency-primary-care/. Accessed 05/05/2017.
52 Murray M, Davies M, Boushon B. Panel Size: How many patients can one doctor manage? Fam Pract Manag. 2007;14(4):44-51.
53 Practice Management Network. Improving Access, responding to patients: A how-to guide for GP practices. Department of Health; 2009.
54 Balasubramanian H, Banerjee R, Denton B, Naessens J, Stahl J. Improving clinical access and continuity through physician panel redesign. J Gen Intern Med. 2010;25(10):1109-1115.20549379
55 Balasubramanian H, Biehl S, Dai L, Muriel A. Dynamic allocation of same-day requests in multi-physician primary care practices in the presence of prescheduled appointments. Health Care Manag Sci. 2014;17(1):31-48.23821343
56 Green LV, Savin S, Murray M. Providing timely access to care: what is the right patient panel size? Jt Comm J Qual Patient Saf. 2007;33(4):211-218.17441559
57 Robinson L, Chen R. A comparison of traditional and open-access policies for appointment scheduling. Manufacturing & Service Operations Management. 2010;12(2):330-346.
58 Strindhall M, Henriks G. How improved access to healthcare was successfully spread across Sweden. Qual Manag Health Care. 2007;16(1):16-24.17235248
59 Kilo CM, Triffletti P, Tantau C, Murray M. Improving access to clinical offices. J Med Pract Manage. 2000;16(3):126-132.11280199
60 Cherniack EP, Sandals L, Gillespie D, Maymi E, Aguilar E. The use of open-access scheduling for the elderly. J Healthc Qual. 2007;29(6):45-48.
61 Murray M, Tantau C. Same-day appointments: exploding the access paradigm. Fam Pract Manag. 2000;7(8):45-50.
62 Murray M, Tantau C. Redefining open access to primary care. Manag Care Q. 1999;7(3):45-55.10620958
63 Shea BJ, Grimshaw JM, Wells GA, . Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Medical Research Methodology. 2007;7(1):1.17217545
64 Department of Veterans Affairs. Resources - PACT - Patient Care Services. http://www.patientcare.va.gov/primarycare/pact/Resources.asp. Accessed 5/5/2017.
65 Cleveland Clinic. Cleveland Clinic President, CEO Toby Cosgrove, M.D., Delivers Annual State Of The Clinic Address: 2016 highlights included expanded access, improved quality, more affordable care. Newsroom 2017; https://newsroom.clevelandclinic.org/2017/02/15/cleveland-clinic-president-ceo-toby-cosgrove-m-d-delivers-annual-state-clinic-address/. Accessed 5/5/2017.
66 VA Office of Research & Development Center for Imformation Dissemination and Education Resources. FORUM, Fall 2015. 2015; www.hsrd.research.va.gov/publications/forum. Accessed 05/05/2017.