# METHODS

## TOPIC DEVELOPMENT

This topic was developed in response to a nomination by Drs. Stephan Fihn and Joseph Francis in the Office of Analytics and Business Intelligence and Susan Kirsh in the Office of Clinical Operations (10NC). Key questions were then developed with input from the topic nominator, the ESP coordinating center, the review team, and the technical expert panel (TEP).

The aim of this review is to determine what evidence is available to support improved organizational management of access in a multi-level organization such as VA. Considering studies of interventions to improve organizational management of access, the Key Questions nested within this aim are:

1. What definitions and measures of intervention success are used, and what evidence supports use of these definitions and measures?
2. What samples or populations of patients are studied, including eligibility criteria?
3. What are the salient characteristics of local and organizational contexts studied?
4. What are the key features of successful (and unsuccessful) interventions for organizational management of access?
5. Are relevant, tested tools, toolkits, or other detailed material available from successful organizational interventions?

The review was not registered in PROSPERO because it did not fit the PROSPERO format.

## TECHNICAL EXPERT PANEL

The plan for and conduct of this review was assisted by input received from a group of technical experts: Susan Kirsh, National Director Clinic Practice Management; Idamay Curtis, Administrative Director of the PACT Demo Lab Initiative; Greg Orshansky, Lead Physician, Primary Care at West Los Angeles VA Medical Center; Danielle Rose, Research Health Scientist at the Center for the Study of Healthcare Innovation, Implementation and Policy; Susan Stockdale, Research Health Scientist at the Center for the Study of Healthcare Innovation, Implementation and Policy; and Lisa Rubenstein, Associate Director, Center for the Study of Healthcare Innovation, Implementation & Policy.

## SEARCH STRATEGY

We searched CINAHL (2005 through 9/19/2016) and PubMed (2005 through 3/3/2016) for relevant literature using key terms relating to group practice management and access or accessibility. Other search strategies were investigated that were broader in scope, but they generated much larger numbers of citations (N=3,718 and over 100,000) and no relevant articles were found in a review of the first 500 titles. The final search strategy, as well as the rejected search strategies, are available in Appendix A. In addition to these searches, we also included references from expert recommendations and any relevant citations from screened publications.

## STUDY SELECTION

All titles were screened for retrieved citations by the Principal Investigator. Abstracts were then screened for relevant citations. For those abstracts deemed relevant, full-text articles were retrieved and screened. Three types of full-text articles were included. The first type of articles were ones that used the term “access” in the context of primary care and management. The second type included interventions in primary care to increase access via a management strategy. These were screened against the following PICOTS framework, which describes our inclusion criteria:

Study design: Hypothesis testing studies and descriptive studies of access to primary care and management strategies to increase access

Population(s): Primary care patients

Intervention(s): Interventions to manage access to primary care

Comparator(s): Usual care

Outcome(s): Access to care

Timing: No restrictions

Setting: Primary care practitioners in high-income countries with emphasis on USA

The final type of included full-text articles included those that described toolkits.

## DATA ABSTRACTION

All data were abstracted by a single reviewer with data checking by second reviewer. Data abstracted from each publication included: definition of access used; evidence to support the definition; description of the sample of patients; setting or context; study design; sample size; duration; results; and data needed to complete the quality assessment.

## QUALITY ASSESSMENT

Risk of bias was assessed using criteria developed for quality improvement intervention publications. Publications reporting on intervention studies were assessed using a modified version of the Quality Improvement Minimum Quality Criteria Set (QI-MQCS, see Appendix B).^5^

## DATA SYNTHESIS

This is a narrative review.

## RATING THE BODY OF EVIDENCE

We rated the body of evidence for Key Questions 1 through 4 based on the GRADE working group.^6^ The quality of the evidence was categorized as follows:

High: We are very confident that the true effect lies close to that of the estimate of the effect.

Moderate: We are moderately confident in the effect estimate: The true effect is likely to be close to the estimate of the effect, but there is a possibility that it is substantially different.

Low: Our confidence in the effect estimate is limited: The true effect may be substantially different from the estimate of the effect.

Insufficient: We have very little confidence in the effect estimate: The true effect is likely to be substantially different from the estimate of effect.

GRADE evaluates the quality of the evidence across all identified studies contributing to the outcome of interest.

## PEER REVIEW

A draft version of the report was reviewed by technical experts and clinical leadership. Reviewer comments and our response are documented in Appendix C.