# APPENDIX F MEASUREMENT OF THIRD NEXT AVAILABLE

Author, Year Title | Description of Measurement
Solberg, 2004^42^ “Key issues in transforming health care organizations for quality: the case of advanced access” | “Because the appointment data had originally been collected for individual physicians, data analysis required accounting for the fulltime equivalent (FTE) status of each physician and nurse practitioner for adults and then calculating a mean access interval for each clinic for each month from June 1999 through August 2002.”
Boushon, 2006^22^ “Using a virtual breakthrough series collaborative to improve access in primary care.” | “The main outcome measure for the VBTS, as for traditional BTS collaboratives working on reduction in waiting times, was the average number of days to third-next-available appointment.”
Steinbauer, 2006^46^ “Implementing open-access scheduling in an academic practice.” | “We diligently tracked our backlog by measuring the time until the third available appointment for a brief visit and found that it varied from one provider to another in a range from 10 to 25 days.”
NHS Salisbury, 2007^38^ “Impact of Advanced Access on access, workload, and continuity: controlled before-and-after and simulated-patient study” | “In a ‘simulated-patient’ study, the researchers telephoned each practice once a month for 11 consecutive months to make an appointment with a doctor. Each attempt to contact the practice was on a randomly selected day of the week and within a randomly selected time slot. If the telephone was busy, diverted to an answer machine, and/or not answered within 2 minutes, up to 5 further calls were made during the time slot. Six attempts to contact each practice involved a request for an appointment with any doctor and 5 with a randomly selected named doctor. The time taken to make telephone contact and the wait for the first and the third available appointments were recorded (the third available appointment has been advocated as a better measure because it avoids fluctuations due to short-notice cancellations, but is more difficult to collect reliably). If the receptionist was not able to offer any appointments, offered alternatives were recorded.”
Dixon, 2006^23^ “Advanced access: more than just GP waiting times?” | “Three measures of access to primary care services were used: time to third appointment (TTTA) with a GP; TTTA with a nurse; and percentage of patients seen on day of choice. The choice of TTTA as the measure of access is common to other evaluations of advanced access, and is justified on the basis that taking the 1st or 2nd available appointment is highly subject to random effect.”
Mehrotra, 2008^29^ “Implementing open-access scheduling of visits in primary care practices: a cautionary tale” | “We calculated the 3rd available appointment measure for each practice based upon each provider's 3rd available time and weighted by the number of practice sessions the provider worked each week. In calculating the 3rd available appointment, we counted calendar days (eg, including weekends) and days off. Although part of open access implementation includes eliminating carve-out appointments (appointments which are closed to scheduling until they are made available for urgent visits the day of or the day prior to those visits), one practice retained these appointments, and we did not count them unless they had been released for booking. We also did not count appointments for providers on maternity leave or other extended absences, and those for temporary and urgent care providers. If providers were on vacation, they were included. All 3rd available measurements reported were collected at a consistent day and time (ie Mondays before the practices opened) and were collected by 3 members of the open access implementation team either manually or via automated scheduling systems when available. Data checks were done to ensure the 3 study staff were collecting data in a comparable manner. During the implementation period we collected data on 3rd available appointment at least monthly. We trained practice staff to measure their own 3rd available times, and when practices began their own data collection or when no changes were being made within the practice, we collected data less frequently. We did not include 3rd available times collected by practices in our analyses.”
Bennett, 2009^21^ “The effect of a carve-out advanced access scheduling system on no-show rates” | “On the first working day of each month, each provider's schedule was checked, and their third-next available appointment for continuity appointments was recorded.”
Cameron, 2010^45^ “Adoption of open-access scheduling in an academic family practice | “This value was calculated approximately weekly for each physician in both practices and tabulated in a spreadsheet. The values for all physicians were averaged to determine the average clinic wait time by month.”
Tseng, 2015^47^ “Implementation of Advanced Access in a Family Medicine Residency Practice” | “The first measure we tracked was third next available appointments (Figure 1). Because this value changes constantly, we chose to run the report on the Monday morning of each week. The average third next available appointment represents the individual provider average rather than the team average. The median is reported in a similar way. We noted a difference between our average and median third next available, which reflects several individual providers with high third next available numbers.”
Harris, 2015^25^ “Impact of a quality improvement program on primary healthcare in Canada: A mixed-method evaluation” | “The survey included instructions for measuring the number of days until the third-next-available appointment, and a table to complete with the dates for the first, second, and third-next-available appointment (including date and time of measurement). To reduce the effect of seasonal changes on appointment variability, the surveys were sent once all physicians were recruited for the chart audit.”
MacCarthy, 2012^28^ “Improving primary care in British Columbia, Canada: evaluation of a peer-to-peer continuing education program for family physicians” | “… wait times (in days) on urgent, regular and third next available appointments, based on estimates given by all GP respondents”