# APPENDIX E CITATIONS OF FULL-TEXT EXCLUDES

## Not evaluations/Design

1 Anderson DR. Evaluating open access: problems with the program or the studies? Ann Intern Med. 2008;149(12):909-910; author reply 911.
2 Craighead I. Pracices in UK are working harder, not more efficiently. BMJ 2001(323):804.
3 Kellermann AL. Evaluating open access: problems with the program or the studies? Ann Intern Med. 2008;149(12):910-911; author reply 911.
4 Manard W. How to Provide MORE ACCESS Without Working More Hours. Family Practice Management. 2015;22(3):24-29.
5 Salisbury C. Does advanced access work for patients and practices? Br J Gen Pract. 2004;54(502):330-331.15113512
6 Salisbury C. Evaluating open access: problems with the program or the studies? Ann Intern Med. 2008;149(12):910; author reply 911.
7 Health Do. Achieving and sustaining improved access to Primary Care. Department of Health;2002.
8 Murray M, Tantau C. Redefining open access to primary care. Manag Care Q. 1999;7(3):45-55.10620958
9 Oldham J. Advanced Access in Primary Care. Glossop, National Primary Care Development Team;2001.
10 Valenti WM, Bookhardt-Murray J. Advanced-access scheduling increases quality, productivity, and revenue. AIDS Read. 2004;14(5):220-224.15198080

## Not about access

11 Alessandrini E, Strauss A. Developing and Implementing a Standard Dashboard for All Medical and Surgical Divisions at Cincinnati Children's Hospital. 2012 ELAM Institutional Action Project Poster Symposium. 2012.
12 Hill RD, Luptak MK, Rupper RW, . Review of veterans health administration telemedicine interventions. Am J Manag Care. 2010;16(12 Suppl):e302-310.21322300
13 Lasser KE, Mintzer IL, Lambert A, Cabral H, Bor DH. Missed appointment rates in primary care: the importance of site of care. J Health Care Poor Underserved. 2005;16(3):475-486.16118837
14 Mitchell V. Same-day booking: success in a Canadian family practice. Can Fam Physician. 2008;54(3):379-383.18337532
15 White D, Froehle C, Chima A, Hamilton R. Pulmonary Clinic Flow Simulation Model review (A PowerPoint Presentation on 5/27/2010) Division of Health Policy & Clinical Effectiveness, Cincinnati Childeren's. 2010.
16 White D. Modification of System Schedule: Simulation Model Output Results (A PowerPoint Presentation on 12/20/2010) GI Clinic Flow Project, James M Anderson Center for Health Systems Excellence, Cincinnati Children's. 2010.

## Access other than getting primary care appointment

17 Bleustein C, Rothschild DB, Valen A, Valatis E, Schweitzer L, Jones R. Wait times, patient satisfaction scores, and the perception of care. The American journal of managed care. 2014;20(5):393-400.25181568
18 Cincinnati Children's. Managing Capacity to Improve Access.

## Specific population

19 Shannon GR, Wilber KH, Allen D. Reductions in costly healthcare service utilization: findings from the Care Advocate Program. J Am Geriatr Soc. 2006;54(7): 1102-1107.16866682
20 Solberg LI, Crain AL, Sperl-Hillen JM, Hroscikoski MC, Engebretson KI, O'Connor PJ. Effect of improved primary care access on quality of depression care. Ann Fam Med. 2006;4(1):69-74.16449399
21 Sperl-Hillen JM, Solberg LI, Hroscikoski MC, Crain AL, Engebretson KI, O'Connor PJ. The effect of advanced access implementation on quality of diabetes care. Prev Chronic Dis. 2008;5(1):A16.18082005
22 Newman ED, Harrington TM, Olenginski TP, Perruquet JL, McKinley K. “The rheumatologist can see you now”: Successful implementation of an advanced access model in a rheumatology practice. Arthritis Rheum. 2004;51(2):253-257.15077268
23 Mallard SD, Leakeas T, Duncan WJ, Fleenor ME, Sinsky RJ Same-day scheduling in a public health clinic: a pilot study. J Public Health Manag Pract. 2004;10(2):148-155.14967982
24 Woodcock EW, Whicker E, Hostetler L, Nichols D. Remove Roadblocks and Improve Access to Preventive Care. Family Practice Management. 2011;18(5):26-30.21923075

## No outcomes of interest

25 Ahluwalia S, Offredy M. A qualitative study of the impact of the implementation of advanced access in primary healthcare on the working lives of general practice staff. BMC Fam Pract 2005;6:39.16188036
26 Conrad D, Fishman P, Grembowski D, . Access intervention in an integrated, prepaid group practice: effects on primary care physician productivity. Health Serv Res. 2008;43(5 Pt 2): 1888-1905.18662171
27 Gladstone J, Howard M. Effect of advanced access scheduling on chronic health care in a Canadian practice. Can Fam Physician. 2011;57(1):e21-25.21252121
28 Lewandowski S, O'Connor PJ, Solberg LI, Lais T, Hroscikoski M, Sperl-Hillen JM. Increasing primary care physician productivity: A case study. Am J Manag Care. 2006; 12(10): 573-576.17026411
29 O'Connor ME, Matthews BS, Gao D. Effect of open access scheduling on missed appointments, immunizations, and continuity of care for infant well-child care visits. Arch Pediatr Adolesc Med. 2006;160(9):889-893.16953011
30 O'Hare CD, Corlett J. The outcomes of open-access scheduling. Fam Pract Manag. 2004;11(2):35-38.
31 Palen TE, Ross C, Powers JD, Xu S. Association of online patient access to clinicians and medical records with use of clinical services. Jama. 2012;308(19):2012-2019.23168824
32 Pickin M, O'Cathain A, Sampson F, Salisbury C, Nicholl J. The impact of Advanced Access on antibiotic prescribing: a controlled before and after study. Fam Pract. 2010;27(5): 554-555.20547495
33 Solberg LI, Maciosek MV, Sperl-Hillen JM, . Does improved access to care affect utilization and costs for patients with chronic conditions? Am J Manag Care. 2004; 10(10):717-722.15521163
34 Subramanian U, Ackermann RT, Brizendine EJ, . Effect of advanced access scheduling on processes and intermediate outcomes of diabetes care and utilization. J Gen Intern Med. 2009;24(3):327-333.19132326
35 Tufano JT, Ralston JD, Martin DP. Providers' experience with an organizational redesign initiative to promote patient-centered access: a qualitative study. J Gen Intern Med. 2008;23(11): 1778-1783.18769981

## Background relevant only

36 Cherniack EP, Sandals L, Gillespie D, Maymi E, Aguilar E. The use of open-access scheduling for the elderly. J Healthc Qual. 2007;29(6):45-48.
37 Degani N. Impact of advanced (open) access scheduling on patients with chronic diseases: an evidence-based analysis. Ont Health Technol Assess Ser. 2013;13(7):1-4
38 Kiran, T., & O'Brien, P. (2015). “Challenge of same-day access in primary care.” Canadian Family Physician 61(5): 399-400.25971751
39 Murray M, Tantau C. Same-day appointments: exploding the access paradigm. Fam Pract Manag. 2000;7(8):45-50.
40 Murray M, Bodenheimer T, Rittenhouse D, Grumbach K. Improving timely access to primary care: case studies of the advanced access model. Jama. 2003;289(8): 1042-1046.12597761
41 Murray M. Answers to your questions about same-day scheduling. Fam Pract Manag. 2005;12(3):59-64.
42 Price RA, Elliott MN, Zaslavsky AM, . Examining the role of patient experience surveys in measuring health care quality. Medical Care Research and Review. 2014;71(5): 522-554.25027409
43 Rose KD, Ross JS, Horwitz LI Advanced access scheduling outcomes: a systematic review. Arch Intern Med. 2011;171(13):1150-1159.21518935

## Not an intervention

44 Bishop TF, Press MJ, Mendelsohn JL, Casalino LP. Electronic communication improves access, but barriers to its widespread adoption remain. Health Aff (Millwood). 2013;32(8): 1361-1367.23918479
45 Bowie P, McNab D, Ferguson J, . Quality improvement and person-centredness: a participatory mixed methods study to develop the ‘always event’ concept for primary care. BMJ Open. 2015;5(4):e006667.
46 Cowling, T. E., Cecil, E. V., Soljak, M. A., Lee, J. T., Millett, C., Majeed, A., … & Harris, M. J. (2013). “Access to primary care and visits to emergency departments in England: a cross-sectional, population-based study.” PloS one 8(6): e66699.23776694
47 Kilo CM, Triffletti P, Tantau C, Murray M. Improving access to clinical offices. J Med Pract Manage. 2000;16(3): 126-132.11280199
48 Knox L, Taylor EF, Geonnotti K, . Developing and Running a Primary Care Practice Facilitation Program A How To Guide. Mathematica Policy Research;2011.
49 Mian, O., & Pong, R. (2012). “Does better access to FPs decrease the likelihood of emergency department use? Results from the Primary Care Access Survey. .” Canadian Family Physician 58(11): e658-e666.23152473
50 Neuwelt PM, Kearns RA, Browne AJ. The place of receptionists in access to primary care: Challenges in the space between community and consultation. Soc Sci Med. 2015;133:287-295.25455478
51 van den Berg, M. J., van Loenen, T., & Westert, G. P. (2016). “Accessible and continuous primary care may help reduce rates of emergency department use. An international survey in 34 countries.” Family Practice 33(1): 42-50.26511726
52 Wensing M, van den Hombergh P, Akkermans R, van Doremalen J, Grol R. Physician workload in primary care: what is the optimal size of practices? A cross-sectional study. Health Policy. 2006;77(3):260-267.16129508

## Duplicate

53 Lukas, C. V., Meterko, M. M., Mohr, D., Seibert, M. N., Parlier, R., Levesque, O., & Petzel, R. A. (2008). “Implementation of a clinical innovation: the case of advanced clinic access in the Department of Veterans Affairs.” The Journal of ambulatory care management, 31(2): 94-108.18360170

## Not Available

54 Lamb J. Why ‘advanced access’ is a retrograde step. Br J Gen Pract. 2002(52):1035.
55 Loomis LM, B. Effect of Advanced Access Scheduling on Continuity in a Community Health Centre. Paper presented at: NAPCRG Conference2005; Quebec, Canada.