# APPENDIX D EVIDENCE TABLE

Author, Year Title | Definition of Access | Evidence to support it | Sample of patients | Settings
Studies of interventions to improve access
Radel, 2001^35^ “Redesigning clinical office practices to improve performance levels in an individual practice association model HMO” | Wait time for an appointment | None | Patients of a not-for-profit HMO in New York | Two clinical office practices in Buffalo, New York, one site was suburban with 5 PCPs and the other site was a solo practitioner with 4,500 patients and 2.5 support staff
Kennedy, 2003^26^ “Implementation of an open access scheduling system in a residency training program” | Utilization | None | Patients of an academic family medicine practice | An academic family medicine practice seeing 24,000 visits annually with 3.3 faculty physicians FTE, 5.2 resident FTE, and 4.3 non-physician FTE
Kennedy, 2003^26^ “Implementation of an open access scheduling system in a residency training program” | Patient satisfaction | None | Patients of an academic family medicine practice | An academic family medicine practice seeing 24,000 visits annually with 3.3 faculty physicians FTE, 5.2 resident FTE, and 4.3 non-physician FTE
Meyers, 2003^30^ “Changing business practices for appointing in military outpatient medical clinics: the case for a true “open access” appointment scheme for primary care” | Third next available appointment | None | Military TRICARE patients attending a military family medicine clinic | A military family medicine clinic
Meyers, 2003^30^ “Changing business practices for appointing in military outpatient medical clinics: the case for a true “open access” appointment scheme for primary care” | Continuity (% patients assigned a PCP who were seen by PCP) | None | Military TRICARE patients attending a military family medicine clinic | A military family medicine clinic
Belardi, 2004^20^ “A controlled trial of an advanced access appointment system in a residency family medicine center” | Third next available appointment | None | Patients of an academic family medicine clinic | An academic family medicine clinic in Pennsylvania
Belardi, 2004^20^ “A controlled trial of an advanced access appointment system in a residency family medicine center” | Continuity (PCP-patient match, percentage of patient visits with patient-identified PCP) | None | Patients of an academic family medicine clinic | An academic family medicine clinic in Pennsylvania
Solberg, 2004^42^ “Key issues in transforming health care organizations for quality: the case of advanced access” | Third next available appointment | Using first available appointment is “erroneous” | About 240,000 patients of HealthPartners Medical Group | 17 HealthPartners clinics in Minnesota
Armstrong, 2005^19^ “Reinventing Veterans Health Administration: focus on primary care” | Mean number of days between date the appointment was fist requested and the date the appointment was actually scheduled | None | All VA primary care patients | Nationwide VA primary care clinics
Armstrong, 2005^19^ “Reinventing Veterans Health Administration: focus on primary care” | Third next available appointment | None | All VA primary care patients | Nationwide VA primary care clinics
Schall, 2004^41^ “Improving patient access to the Veterans Health Administration's primary care and specialty clinics” | Next available appointment | None | Veteran patients visiting a VA primary care clinic | VA primary care clinic in New York
Lukas, 2008^27^ “The Implementation and Effectiveness of Advanced Clinic Access” | Next available appointment | None | Veterans patients visiting on of the included medical centers | Sample of 78 VA medical centers purposively sampled to capture high, medium, and low wait times
Parente, 2005^31^ “A pre-post comparison of service operational efficiency and patient satisfaction under open access scheduling” | PCP access (Whether the patient saw their PCP during that appointment) | None | Patients of a pediatric practice | A four-clinician academic pediatric practice
Boushon, 2006^22^ “Using a virtual breakthrough series collaborative to improve access in primary care.” | Third next available appointment | Mention IHI | Patients at 17 organizations | 17 organizations, no contextual description provided
Steinbauer, 2006^46^ “Implementing open-access scheduling in an academic practice.” | Third next available appointment | None | Patients at Baylor family medicine in Houston | Academic urban primary care practice
Sampson, 2008^40^ “Impact of same-day appointments on patient satisfaction with general practice appointment systems Pickin, 2004^33^ “Evaluation of advanced access in the national primary care collaborative” Windridge, 2004^44^ “Problems with a ‘target’ approach to access in primary care: a qualitative study” | Patient satisfaction with the appointment system | None | 12,825 adult patients in English general practice | 48 general practices in England
Salisbury, 2007^38^ “Impact of Advanced Access on access, workload, and continuity: controlled before-and-after and simulated-patient study.” | Next available appointment Third next available | “third available has been advocated because it avoids fluctuations due to short-notice cancellations”
Salisbury, 2007^38^ “Impact of Advanced Access on access, workload, and continuity: controlled before-and-after and simulated-patient study.” | Continuity of Care index Waits for particular MD | Citation for index None
Dixon, 2006^23^ “Advanced access: more than just GP waiting times?” Goodall, 2006 ^24^ “Implementation of Advanced Access in general practice: postal survey of practices” Salisbury, 2007^37^ “Does Advanced Access improve access to primary health care? Questionnaire survey of patients” | Third next available appointment | None | Patients at English general practices | 462 English general practices
Salisbury, 2007^39^ “An evaluation of Advanced Access in general practice” | Third next available appointment | None | Data were collected by “secret shoppers” calling practices to get appointments | 47 general practices in England
Salisbury, 2007^39^ “An evaluation of Advanced Access in general practice” | Continuity (patient seeing doctor they ideally wanted to see) | None | Data were collected by “secret shoppers” calling practices to get appointments | 47 general practices in England
Pope, 2008^34^ “Improving access to primary care: 8 case studies of introducing Advanced Access in England.” | None | None | Patients at English general practices | 8 general practices in England
Rohrer, 2007^36^ “Impact of open-access scheduling on realized access” | Primary care visits for evaluation and management | None | 1,410 family medicine patients classified as “chronic-stable” according to Adjusted Clinical Groups | Four Mayo clinics in different geographic locations
Rohrer, 2007^36^ “Impact of open-access scheduling on realized access” | “Other primary visits for preventative care” | None | 1,410 family medicine patients classified as “chronic-stable” according to Adjusted Clinical Groups | Four Mayo clinics in different geographic locations
Mehrotra, 2008^29^ “Implementing open-access scheduling of visits in primary care practices: a cautionary tale” | Third next available appointment time | “Thought to be more stable” | Patients of Partners Community Health Care, no other details given | Six practices participating in an advanced access initiative in Massachusetts
Bennett, 2009^21^ “The effect of a carve-out advanced access scheduling system on no-show rates” | Third next available appointment | Cites working paper from IHI | Patients of a family medicine clinic in South Carolina. 74 percent female, 68 percent black, 2 percent self-pay, 14 percent Medicaid, 47 percent aged 45-64 years | Academic urban family practice clinic seeing 30,000 visit/year. Staffed by 14 faculty MDs, 30 residents, 4 fellows, one nurse practitioner. Panel size = 100 patients/half day
Bennett, 2009^21^ “The effect of a carve-out advanced access scheduling system on no-show rates” | No-show rate | None | Patients of a family medicine clinic in South Carolina. 74 percent female, 68 percent black, 2 percent self-pay, 14 percent Medicaid, 47 percent aged 45-64 years | Academic urban family practice clinic seeing 30,000 visit/year. Staffed by 14 faculty MDs, 30 residents, 4 fellows, one nurse practitioner. Panel size = 100 patients/half day
Bennett, 2009^21^ “The effect of a carve-out advanced access scheduling system on no-show rates” | Continuity (proportion of appointments scheduled with PCP | None | Patients of a family medicine clinic in South Carolina. 74 percent female, 68 percent black, 2 percent self-pay, 14 percent Medicaid, 47 percent aged 45-64 years | Academic urban family practice clinic seeing 30,000 visit/year. Staffed by 14 faculty MDs, 30 residents, 4 fellows, one nurse practitioner. Panel size = 100 patients/half day
Phan, 2009^32^ “Decreased continuity in a residency clinic: a consequence of open access scheduling.” | Continuity indices | Two previously used indices (Usual Provider Continuity Index and Modified Modified Continuity Index) | 2,208 patients seen at Family Medical Center | Family Medicine Center in Phoenix with about 12,000 visits/year. Academic, urban site, with 32 physicians (24 residents, 8 faculty)
Tantau, 2009^43^ “Accessing patient-centered care using the advanced access model.” | Third next available appointment | “anchor metric for Advanced Access… more reliably reflects when the schedule actually has substantial capacity” | Patients of 2 organizations | Ministry Medical Group is multisite organization in Wisconsin with variability in site characteristics Providence Community Health Centers at Capitol Hill HC is in a urban setting in Rhode Island.
Cameron, 2010^45^ “Adoption of open-access scheduling in an academic family practice | Third next available appointment Utilization No-show rate | Cites a working paper from IHI | Patients of 2 family medicine clinics in Halifax, Nova Scotia | 2 family medicine clinics, one serving 20,000 patient visits/year and the other 10,000 patient visits/year
Tseng, 2015^47^ “Implementation of Advanced Access in a Family Medicine Residency Practice” | Third next available appointment | None | OHSU Family Medicine Clinic (panel of 12,000 patients, “Spanning a wide range of ages and socioeconomic backgrounds”) | Academic Family Medicine Residency Program
Tseng, 2015^47^ “Implementation of Advanced Access in a Family Medicine Residency Practice” | Patient continuity by team | None | OHSU Family Medicine Clinic (panel of 12,000 patients, “Spanning a wide range of ages and socioeconomic backgrounds”) | Academic Family Medicine Residency Program
Tseng, 2015^47^ “Implementation of Advanced Access in a Family Medicine Residency Practice” | (Percentage of patients assigned to a PCP who had seen their PCP during the month) Press-Ganey satisfaction (“ease of scheduling appointments”) | None | OHSU Family Medicine Clinic (panel of 12,000 patients, “Spanning a wide range of ages and socioeconomic backgrounds”) | Academic Family Medicine Residency Program
Harris, 2015^25^ “Impact of a quality improvement program on primary healthcare in Canada: A mixed-method evaluation” | Third next available appointment | None | Patients seeing providers that participated in the Quality Improvement and Innovation Partnership (QIIP). Patient demographics for both QIIP and control are provided for subgroups including those providing foot exam, A1c, and colorectal cancer screening data in Table 3 of the publication. | Family Health Teams and Community Health Centers in Ontario, Canada
MacCarthy, 2012^28^ “Improving primary care in British Columbia, Canada: evaluation of a peer-to-peer continuing education program for family physicians” | Next available urgent appointment Next available regular appointment Third next available appointment | None | Patients of 157 general practitioners and 109 medical office assistants who participated in the advanced access module of the intervention | Primary care practices in British Columbia, Canada
Studies about primary care access, but not hypothesis test of actual intervention
Murray & Bewick, 2003^13^ | None. This is a commentary about advanced access, with access classified only as “delays in care”
Pierdon, 2004^15^ “Implementing advanced access in a group practice network” | Third next available appointment | None | Geisinger Health System patients | Geisinger Health System clinics
Green, 2007^56^ “Providing timely access to care: what is the right patient panel size?” | Overflow frequency level (The fraction of days when demand exceeds the average number of appointments available) | None | None. This is a modeling study.
NHS, 2009^53^ “Improving Access, responding to patients: A how-to guide for GP practices” | “Good access” is about: -Patients being able to book an appointment quickly, within a reasonable time frame, and pre-book one if they wish -Patients being able to see a preferred clinician if they wish to wait longer for an appointment | None | None. This is a how-to guide | English National Health Source General Practitioners Practices
Balasubramanian, 2010^54^ “Improving clinical access and continuity through physician panel redesign” | Wait time (until appointment with PCP) | None | None. This is a mathematical modeling study that assesses how the composition of a panel can be organized to increase access
Balasubramanian, 2010^54^ “Improving clinical access and continuity through physician panel redesign” | Continuity with PCP | None | None. This is a mathematical modeling study that assesses how the composition of a panel can be organized to increase access
Balasubramanian, 2013^55^ “Dynamic allocation of same-day requests in multi-physician primary care practices in the presence of prescheduled appointments” | “Timely access” “Continuity of care” | “Two operational measures important for primary care” | None. This is a mathematical modeling study that assesses where in a normal workday pre-scheduled appointments influence access and continuity.
Knight, 2013^12^ “Appointments 101--how to shape a more effective appointment system.” | Third next available appointment | None | None. This is an article that “shares lessons from the Australia Primary Care Collaborative” | Primary care
Knight, 2013^12^ “Appointments 101--how to shape a more effective appointment system.” | “Unmet demand” (a weekly tally of how many patients could not be given an appointment) | None | None. This is an article that “shares lessons from the Australia Primary Care Collaborative” | Primary care
Knight, 2013^12^ “Appointments 101--how to shape a more effective appointment system.” | “Patient satisfaction” (“I was able to make an appointment on the day I wanted with the clinician I wanted to see”) | None | None. This is an article that “shares lessons from the Australia Primary Care Collaborative” | Primary care
Berry, 2014^8^ “Toward a strategy of patient-centered access to primary care” | Patient-centered access is defined as “consistently providing convenient access to services that patients need and desire” | None | None. This is a commentary/how-to guide | None
Donahue, 2015^18^ “Tackling the Triple Aim in Primary Care Residencies: The I3 POP Collaborative” | Usual provider continuity (not otherwise defined) | “The triple aim” | 300,000 patients in North Carolina, South Carolina, and Virginia; not otherwise described | 27 primary care residents program
Donahue, 2015^18^ “Tackling the Triple Aim in Primary Care Residencies: The I3 POP Collaborative” | Third next available appointment | “The triple aim” | 300,000 patients in North Carolina, South Carolina, and Virginia; not otherwise described | 27 primary care residents program