# APPENDIX C PEER REVIEW COMMENTS/AUTHOR RESPONSES

Comment | Response
Although ref 41 describes VA's ACA initiative, the publication is an abbreviated version of the complete report which is readily available. http://www.researchgate.net/publication/228478818 This report has much more detail re: context. | We actually used the full report but erroneously cited the abbreviated version. This has been corrected.
There are additional modeling studies that are relevant, eg, Robinson LW, Chen RR. A comparison of traditional and open-access policies for appointment scheduling. Manufacturing & Service Operations Management 2010;12;330-346. | We have now included this in our modeling studies section, our search did not identify this article.
There is much going on in the world of improving access than is reflected in the academic literature. For example, the Cleveland Clinic made 1.3 million same day appointments in 2016 and it is possible to get a same day or next day appointment with a specialist - maybe not the individual you wanted, maybe not in the most convenient location, and maybe with a relevant specialty but not the one requested, eg, seeing a neurologist for headache when you asked for a neurosurgeon. I am unaware that this has been published in any academic literature and it may not stand up to scrutiny if evaluated carefully, but this type of information would still be informative. There are almost certainly many other similar efforts going on. | We agree that the possibility of publication bias in this literature review is a limitation, and cite this example when we discuss this issue.
Take a closer look at CAHPS literature (both peer reviewed and ‘gray’) to see usefulness of patient self report as an access measure. | We asked the Principal Investigator of CAHPS (Marc Elliott) for this information and he identified the 2 citations we included. This topic is not a specific key question for this report and we therefore did not do a systematic search on it, but trust the CAHPS PI to identify the relevant research.
What about use of “Secret Shopper calls” - a technique used by McWilliams to assess ACOs and by the California Health Foundation in a recent report? | This comment is about methods for evaluating access, and that was not the subject of our search, which was about actual evaluations, meaning we are limited to studies evaluating access management interventions. In the included studies, the evaluation of the NHS Advanced Access did use secret shopper type techniques and this is noted in the text.
Can we extract - or extrapolate - insights from recent PCMH demonstrations within and outside of VHA? | We did review the PACT Demo Lab materials that were assembled for the related Access Expert Panel as a part of our original material collection.
Is there any indication of bias in our synthesis of the evidence? Yes - Note: I clicked on the Yes in order to make a comment, not with the idea of impugning anyone's integrity. The primary bias to which I am referring is the bias inherent in the method; The bias is that the method privileges certain things as “evidence.” Once this method was chosen, it was conducted in an unbiased fashion. That said, I was very pleased to see the section entitled “additional relevant literature.” However, there is another type of bias that may be present -academic bias. On page 34: “The lack of substantial additional hypothesis-testing studies of the implementation of Advance/Open Access in the past 6 years is a marked contrast to the period 2003-2010, when 15 studies were reported, and suggests that something has shifted in the perception of Advanced/Open Access since 2010.” Alternatively, something has shifted in the perception of academic publication; practitioners who are doing work in the area may not think that academic publication is of value. (in my experience as a professor in both a medical school and business school, the lowest level of evidence perhaps, the research-practice divide is greater in management than it is in medicine.) | An interesting point that we have incorporated with this statement.
This Cochrane type review follows that method just fine. The bigger question is to what extent this approach meets the aim of the review “to determine what evidence is available to support improved organizational management of access in a multi-level organization such as VA.” First, this approach privileges certain statements as evidence and it is a rather narrow view. Second, I have serious doubts that this approach really helps when dealing with such complex social interventions as implementation of advanced/open access. Such interventions are extremely context-dependent and the evidence hierarchy privileges context independent knowledge. In addition, sample sizes are by necessity rather small which makes it difficult to randomize out differences in context. The question for the manager of clinics (and I was one) is not so much what works ON THE AVERAGE, but what works for whom under what circumstances, ie where there are intervention by context interactions. | We first note that had this been a Cochrane review, we would have excluded nearly every study, as there were no randomized controlled trials. The point about “what is evidence” is a valid one. We have expanded our discussion of publication bias to be more inclusive of this point. We produced the AHRQ report entitled “Assessing the Evidence for Context-Sensitive Effectiveness and Safety of Patient Safety Practices,” which highlights the importance of context, and describes key features of context which should be measured and reported. We are attuned to the reviewer's concerns about context-dependent interventions, and we collected context information to the extent possible. Unfortunately, a systematic review can only describe that which was included in the original publications, which is why we described this as a limitation.
I find it astonishing that our approaches to improving access have so little grounding in evidence. That itself is an important finding, although how that should influence policymaking is tougher to assess. Should more research be done? Should our policy interventions occur in a stepwise fashion allowing for evaluation along the way? Should we even abandon standard access metrics altogether to look at something completely different, such as health outcomes? (One possible example to look at would be ACSC Hospitalizations). I was surprised with the “I” recommendation for TNA with no discussion about the relative merits of CAHPS Access items, which currently are the only consistently supported Access measure by NQF and NCQA. Most of the studies were done prior to wide adoption of CAHPS so the relative paucity of that metric is not an indicator of its inadequacy. I have also seen more recent literature that used Secret Shoppers to assess actual access in primary care offices - surprising to me that this technique wasn't mentioned, although it has been used to assess impact of health reform in MA and CA. Finally, it seems to me that this review focused largely on the IHI Open Access/Advanced Access model rather than other approaches to address Access. I think one important finding is that longer duration studies were not able to show sustainment of gains. I worry that this paper demonstrated too much “anchoring” on a single approach and that the literature search may have omitted other potentially valid alternatives (one example that pops into mind is the emerging literature on “Minute Clinics” which could be a useful means to supplement primary care). | This first comment is directed at policymakers and not the report per se. The next comment is a result of the difference between the question we were given “What definitions and measures of intervention success are used?” and the broader question “What are measures of access?” The former question restricts our scope to studies that evaluated a primary care access management intervention. The latter is a broader question that was not in our scope. Perhaps the reviewer could request to the ESP Coordinating Center a need for an ESP report on measures of access. As above, these Secret Shopper studies are studies of access in general, and not studies of evaluations of interventions to improve primary care access; hence they are not in our scope. We note that we were not anchored in any particular approach. We were charged with identifying evaluations of interventions to improve primary care access. As it turns out, nearly all of the published studies identified were about Advanced Access.
This is an excellent product. No substantive criticism or suggestions. A few minor typos: page 23 lines 25 and 52 page 24 line 5 page 32 line 16 | These have been corrected, thank you for pointing them out.
• There have been some evaluations of educational initiatives to adopt advanced access and/or improve access in primary care in Canada. These may not meet criteria for the review but may be worth mentioning in the “additional relevant literature” section: ○ McCarthy et al. “Improving primary care in British Columbia, Canada: evaluation of a peer-to-peer continuing education program for family physicians. BMC Medical Education 2012 ○ Harris et al. “Impact of a quality improvement program on primary healthcare in Canada: A mixed-method evaluation” Health Policy 2014 | Thank you for these suggestions, they do meet our criteria and we have incorporated them.
I was struck by the finding that TNA was the most commonly used measure of success for access interventions but there are no empiric data linking this choice to a health outcome. It would be helpful to understand more details on how TNA was measured. Was TNA measured for each physician in the clinic and then mean or median reported? Was TNA measured on the same day and time of the week (eg, if measured on Monday, TNA always looks better than on Friday if weekends are included)? Were weekends included in the measure? | We have now added more details about TNA measurement in the text and an appendix.
The section on page 14 related to continuity is sparse. There are numerous studies linking continuity to health outcomes and these should be cited. Please see a recent review done in Alberta: http://www.topalbertadoctors.org/file/top--evidence-summary--value-of-continuity.pdf . There was also an excellent study recently published in the BMJ on continuity of care and outcomes: http://www.bmj.com/content/356/bmj.j84 . Usual provider of care index is a standard measure of continuity but some of the other measures of continuity cited as measures used “with no justification” (eg, reference 27, 35) are probably more salient in practices where patients are enrolled or attached to a primary care provider. Continuity is an important balancing measure to access and has been shown to be valued by patients (see: Turner D, Tarrant C, Windridge K, Bryan S, Boulton M, Freeman G, et al. Do patients value continuity of care in general practice? An investigation using stated preference discrete choice experiments. Journal of Health Services Research & Policy. 2007;12(3):132-7) | Our scope was restricted to studies that evaluated a primary care access management intervention. The broader topic about continuity as a measure of access was not in scope, but we appreciate the suggested literature provided and have incorporated them into our discussion of continuity.
When discussing patient satisfaction as an outcome measures, it is important to note that there is value in this measure regardless of its association with health outcomes. Patient experience is one of the 3 points on the “triple aim” and improving patient satisfaction is a worthy goal in and of itself. There are, however, studies linking improved patient reported access with other outcomes. See:; - Browne et al. “Measuring Patient Experience As A Strategy For Improving Primary Care” Health Affairs 2010; - van den Berg MJ, van Loenen T, Westert GP. Accessible and continuous primary care may help reduce rates of emergency department use. An international survey in 34 countries. Family practice. 2016;33(1):42-50; - Cowling TE, Cecil EV, Soljak MA, Lee JT, Millett C, Majeed A, et al. Access to primary care and visits to emergency departments in England: a cross-sectional, population-based study. PloS one. 2013;8(6):e66699.; - Mian O, Pong R. Does better access to FPs decrease the likelihood of emergency department use? Results from the Primary Care Access Survey. Canadian Family Physician. 2012;58(11):e658-e66. | The value of patient satisfaction is an important point, we have now incorporated it into the discussion of patient satisfaction with the Browne and colleagues' article cited. However, our scope was to assess interventions to improve primary care access, and not patient satisfaction per se (which might encompass may different interventions). The other 3 articles (with first authors van den Berg, Cowling, and Mian) fall out of scope for the review since they do not describe interventions, primary care access metrics, or primary care access management tools.
The authors describe advanced access and the related components. Although advanced access is frequently viewed as a set of rules to improve scheduling, it is better understood as a philosophy of care that requires a paradigm shift beginning with physicians feeling accountable for the care of a panel of patients, not appointment slots. I think it's worth discussing this concept. Also, many misinterpret the “rules” in implementation and this is true of the NHS implementation where practices adopted policies of what Murray calls “access by denial” in lieu of doing the hard work of balancing supply and demand. I have discussed this previously in a related commentary I wrote which may be of interest: Kiran et al. Challenge of same-day access in primary care. Canadian Family Physician 2015. | We highlight the components of Advanced Access in response to the key question we were given, which focuses on key features of intervention. This is not to diminish the overarching model of Advanced/Open Access, and we have incorporated this point about the broader Advanced Access philosophy in the section where we describe the components.
The authors report the results of interventions on wait times and continuity. How about the result on emergency department use or chronic disease management? See:; - Solberg LI, Maciosek MV, Sperl-Hillen JM, Crain AL, Engebretson KI, Asplin BR, et al. Does improved access to care affect utilization and costs for patients with chronic conditions? Am J Manag Care 2004;10(10):717-22.; - Subramanian U, Ackermann RT, Brizendine EJ, Saha C, Rosenman MB, Willis DR, et al.Effect of advanced access scheduling on processes and intermediate outcomes of diabetes care and utilization. J Gen Intern Med 2009;24(3):327-33. Epub 2009 Jan 9. | We discussed relevant outcomes with our Technical Expert Panel, and as a result we focused on outcome measures that captured primary care access. While the impact of these interventions on emergency department use and disease management may be valuable impacts of such an intervention, these fall outside the scope of primary care access measures. Both these articles were identified in our searches, but we had excluded them since they did not include primary care access measures.
The article by Pope et al. does discuss unintended consequences related to patient experience. These outcomes could also be mentioned on page 23 | Thank you, we now mention them as you suggest.
Here is an excellent Canadian on-line resource (from Ontario) that was missing from the list: https://machealth.ca/programs/advanced-access-efficiency-primary-care/ | This has been added to the tools discussion.