# APPENDIX A SEARCH STRATEGIES

## FINAL SEARCH STRATEGY

### CINAHL search (starting in 2005, conducted on 9/19/2016)

((MH “Group Practice+” (exploded) OR “group practice”) AND manag*) OR MH “Private Practice Management” OR MH “Practice Management Information Systems” OR “practice management” as keyword

AND

MH “Health Services Accessibility+”(Exploded) OR (health* AND service* AND access*)

Limited to English only and from 2005-2016

### PubMed (starting in 2005, conducted on 3/3/2016)

(“Group Practice”[Mesh] OR group practice*[tiab) AND (management[mh] OR management[tiab] OR manages[tiab] OR managing[tiab] OR manage[tiab])

OR

“Group Practice/organization and administration”[Mesh]

OR

“Practice Management”[Mesh] OR practice manag*[tiab]

AND

“Health Services Accessibility”[Mesh] OR access[ti] OR accessing[ti] OR accessed[ti] OR accessib*[ti]

English only

## REJECTED SEARCH STRATEGIES

### PubMed, limited to English language (starting in 2000, conducted on 10/11/2016)

((primary health care[mh] OR primary care[tiab]) AND practice[tiab]) OR family practice[mh] OR “family practice”[tiab]

AND

“Health Services Accessibility”[Mesh] OR access[tiab] OR accessing[tiab] OR accessed[tiab] OR accessib*[tiab]

AND

organization*[tiab] or (organization and administration[sh]) OR management[majr] OR management[tiab] or manages[tiab] OR managing[tiab] OR manage[tiab]

This search generated 3,718 citations. In a sample of 500 no potential include citations were identified.

This same search was re-run after removing the terms:

((primary health care[mh] OR primary care[tiab]) AND practice[tiab]) OR family practice[mh] OR “family practice”[tiab]

This search generated over 100,000 citations. Screening this many titles would not be feasible.