# ABSTRACT

## INTRODUCTION

Access is a fundamental characteristic of a health care system. All health systems struggle with primary care access. This evidence report was requested by the Office of Analytics & Business intelligence to assess the evidence regarding primary care access management strategies. The key questions asked were:

1. What definitions and measures of intervention success are used, and what evidence supports use of these definitions and measures?
2. What samples or populations of patients are studied, including eligibility criteria?
3. What are the salient characteristics of local and organizational contexts studied?
4. What are the key features of successful (and unsuccessful) interventions for organizational management of access?
5. Are relevant, tested tools, toolkits, or other detailed material available from successful organizational interventions?

## METHODS

We searched PubMed & CINAHL from 2005 through September 2016 for titles related to group practice management and access. Searches of included studies were used for articles published earlier. Studies were included if they assessed primary care patients, an intervention to manage access, and reported an access outcome. Intervention studies were assessed for quality using study design and the Quality Improvement Minimum Quality Criteria Set. The data synthesis was narrative.

## RESULTS

Our literature search identified 979 titles. From these, and including references selected from included studies, 53 publications were included. Of these, 29 publications assessed 19 implementations of interventions to manage primary care access. All were about Advanced or Open Access. All but 3 studies were published between 2001 and 2010.

### Key Question #1 What definitions and measures of intervention success are used, and what evidence supports use of these definitions and measures?

In the studies we identified of management interventions to improve primary care access, the third next available appointment was the most commonly used measure of success (14/19 studies, 74 percent). We identified no empiric data exist linking this choice to any health outcome. The next most commonly used measure of success was continuity (7 studies), followed by patient satisfaction (3 studies). Many publications that discuss access management do not include a definition of access. No evidence supports any measure with clinical outcomes. The third next available appointment measure is believed to be a more stable measure of access than the first or second available appointment.

### Key Question #2 What samples or populations of patients are studied, including eligibility criteria?

The patients who have been included in published studies of access management in primary care have not been described in detail. In general, though, they are likely typical of adult patients attending family medicine clinics, given that many patients came from similar contexts, except for the studies specific to VA.

### Key Question #3 What are the salient characteristics of local and organizational contexts studied?

Little is known about the local and organizational contexts of practice sites included in published studies of primary care access management interventions. Many sites were academically-affiliated clinics, part of the British system, or in the VA.

### Key Question #4 What are the key features of successful (and unsuccessful) interventions for organizational management of access?

All interventions were described by the authors as Advanced Access or Open Access, with 15 of the 19 studies including these phrases in the publication title. The most common intervention components were reducing the backlog of appointments, using fewer appointment types, and producing regular activity report. In 8 studies reporting results of longer than 12 months duration, one study reported initial improvements in access followed by subsequent worsening, one study reported statistically significant decreases in continuity (of uncertain clinical significance), and in 2 implementations across a large number of sites the effect on access was variable.

### Key Question #5 Are relevant, tested tools, toolkits, or other detailed material available from successful organizational interventions?

We identified and retrieved 6 tools or guides for improving primary care access, 4 from settings linked to implementation studies: one from a VA setting, 2 from the IHI/Advanced Access group, and one from the English National Health Service. Two additional online tools came from Canada.

## CONCLUSION/DISCUSSION

A key finding of this review is that evidence about primary care access management is essentially limited to implementation of Advanced/Open Access, with all but 3 publications coming in a ten-year period of time from 2001-2010. Most studies reported dramatic improvements in access. The most commonly used intervention components were reducing the backlog, using fewer appointment types, and setting goals, but whether these are key features of success cannot be determined from the data. Some studies of longer duration reported more mixed results, with rising wait times and the need for modifications to the access management strategy reported in 2 large and long-term studies. Patient populations and contexts have been described at only a basic level. Five toolkits were identified, most coming from settings described in implementation studies.