# SUMMARY AND DISCUSSION

## CONCLUSIONS

[underlined: Key Questions #1 and #1a:] For outpatient care, the majority of studies we identified focused on the association between distance from a VA facility and utilization of VA services for either physical or mental health needs. Increased distance from a VA facility was consistently associated with decreased utilization (fair to good evidence). The pattern was observed for veterans in need of primary care services as well as follow-up care for substance abuse, mental illness, HIV, or spinal cord injury. Another important factor in utilization of VA services was ability to pay for care. Many studies reported increased VA care and use of VA care rather than non-VA care by veterans who were homeless, had an income- or disability-related priority status, or who were service connected. Social support and the presence of comorbid conditions were also factors although the results were less consistent.

For inpatient care, higher admission and readmission rates were generally associated with increased distance from the admitting facility and with increased comorbidity scores. The choice to utilize VA or non-VA inpatient care was inversely related to distance in one study. The condition for which inpatient care was needed was also a factor. One study of facility wait times found increased probability of admission for an ambulatory care sensitive condition for patients visiting facilities with wait times of 29 days or longer.

Few studies included patient-level outcomes. There is limited information about the association between access to care and mortality, quality of life, and perceived health.

[underlined: Key Questions #2 and #2a:] Taken as a whole, the results suggest that access to healthcare can be improved through structural / organizational interventions. All of the articles reported an association between the intervention and at least one measure of access (actual, perceived, or satisfaction with access). The evidence was strongest (fair support) for interventions regarding medication copayments. All four studies included in the review found that increasing medication copayments negatively impacted adherence. Further, the one study that examined system-level outcomes found that the copayment increase led to increased levels of psychiatric hospitalization. However, it is important to note that it is unclear whether decreasing copayments would improve adherence / increase access.

The implementation of CBOCs and PCMH are also promising strategies that warrant more rigorous examination, as the existing studies were generally of low quality. Four studies found a positive association between the opening of CBOCs and access to primary care, while two studies found that veterans were satisfied with CBOCs' accessibility. While none of the CBOC articles were randomized trials, four were fair quality, cohort designs and the sample sizes for a majority of the studies were large, with one being VA-wide. There were six studies that presented data regarding the impact of PCMH integration on access. Two articles examined the impact of integrating mental health services into primary care clinics. Both found that PCMH integration increased access to mental health services. Further, it was found that less intensive models of PCMH implemented within CBOCs also had a significant positive impact on access. Two of the articles, both randomized trials (one fair quality, one good quality), evaluated the efficacy of implementing primary care into mental health clinics. The integration led to self-reported and objective increases in access. Finally, one study (two articles), found that integrating homeless, mental health, and primary care services reduced wait times to primary care to less than one day. Thus, PCMH integration show promise, however, more research on each of the models of integration is needed.

The other intervention that showed promise but requires additional research, was the use of telemedicine. Four studies, one of which was a fair quality RCT, showed that veterans found telemedicine convenient and it led to increased access to providers. The ability of telemedicine to improve access deserves further study, especially in light of findings that interventions delivered via telemedicine yield equivalent outcomes to in-person treatment (e.g., Tuerk et al.58).

A number of other interventions (intensive case management, outreach strategies, copayments, mobile access units, and availability / integration of specialty care) each had one to two articles which examined their efficacy. While all of the interventions either resulted in referrals to additional care, improved wait times, better access to needed treatments (medication), or self-reported satisfaction with access, all require further validation.

Nineteen of the 24 unique studies reported system-level outcomes. The two most frequently reported system-level outcomes were satisfaction with care and number of primary care visits. A large majority of studies that reported satisfaction found that veterans were more satisfied with care following the intervention; the remaining studies found no difference in satisfaction. In regard to primary care and general medical visits, all but one of the studies that reported on those outcomes found that the intervention was associated with increased utilization. Findings regarding the use of specialty care and hospitalization were mixed. Although few studies reported on the outcomes, results were consistent regarding an increase in preventive care and improved engagement in mental health / substance use services following the access intervention.

Finally, only six of the 24 unique studies reported patient-level outcomes. Of those, three reported no significant impact of access on outcomes. One study of PCMH integration found that integration led to better scores on a measure of physical functioning and a second found that a telemedicine intervention led to improvements on mental health related quality of life. A third found mixed results in terms of condition-specific patient-level outcomes.

## LIMITATIONS

There were several important limitations to this study. First, we identified a number of well designed studies that examined access interventions, but they were not included in our review because they did not include data regarding either actual or perceived access outcomes. Therefore, there may be studies that were designed to assess the impact of interventions on access that are not included in this review. We suggest that future research examining access interventions collect and compare measures of perceived and actual access across groups. Further, given the small number of high quality studies and the relatively small number of studies in support of a specific intervention, all findings require further validation.

## RECOMMENDATIONS FOR FUTURE RESEARCH

[underlined: Key Questions #1 and #1a:] Additional research is warranted to further define the relationship between variation in access and variation in system-level and patient-level outcomes. To date, most research has focused on the impact of straight-line distance on utilization but actual travel time and ease of transportation (measures of perceived access) and wait times (for appointments and in clinics) may be important factors to consider. Few studies of inpatient care have looked at associations with ability to pay for care or social support. Many of the studies used existing databases which allow for large sample sizes but limit analyses to variables captured in those databases. For example, few studies could examine the role of non-VA care. Finally, other elements of access (e.g., ways in which veterans needing care enter the VA health care system, costs of care) and other outcomes (e.g., patient satisfaction, improved health status) should be addressed.

[underlined: Key Questions #2 and #2a:] There is a burgeoning literature base which suggests that interventions to increase access to healthcare may be efficacious; however, additional research is required. During our literature review, we identified a number of well designed studies that examined access interventions, but they were not included in our review because they did not include either actual or perceived access outcomes.58-62 When studying interventions hypothesized to improve access, measures of access need to be collected and compared across groups. Not only would this strengthen the evidence base, but would also provide data regarding new / different barriers that may emerge in the intervention condition (e.g., technical difficulties with telehealth services), and lessen the efficacy of the intervention.

The strength of evidence was strongest for the studies that examined the impact of copayments on access (medication adherence). Future research should examine whether a decrease in copayments would increase access to needed medications. Further, the cost of copayment decreases as a method of improving access should be compared to the cost of other, more resource intensive access interventions to determine the relative cost-effectiveness of decreasing medication copayments.

The interventions varied tremendously in their complexity and number of components. Moving forward, it will be important to determine the necessary and sufficient components of access interventions. Further, researchers must begin to focus on the relationship between the level of intervention complexity and the size of its impact on access and other outcomes. Shiner et al.,38 who explored the effectiveness of five levels of PCMH integration, is an example of how such intensity-benefit analyses may be conducted. Within such studies, it will also be important to determine the cost of the intervention and the impact of the intervention on future healthcare costs (some included studies did report cost savings, but those outcomes were not extracted). Then, the complexity, intensity, and cost of the interventions can be considered when evaluating their impact on access. Such cost / benefit analyses may reveal significant benefits to using new, less resource intensive modes of accessing care (e.g., web-based, e-mail, text messaging). Further, moving forward, it will be important to determine the quality of care that veterans are receiving with increased access. As Shiner et al.38 appropriately asked in their title “Access to What?”, in addition to broad measures of access, future research should focus on access to evidence-based, quality care.

Finally, a majority of the articles focused on utilization and few examined patient-level outcomes. The data regarding utilization are difficult to interpret as it is unclear whether increased utilization is a desired, positive outcome. Further, given that utilization data were not linked to patient-level outcomes, it is not possible to determine whether the additional care was necessary and high quality. For example, one of the two good quality RCTs included in the review found that increased access to primary care actually resulted in higher rates of hospital readmission.45 The question of whether more, higher intensity care results in better outcomes has previously been examined in the literature and the findings clearly suggest that access to more care / higher intensity care does not consistently lead to better outcomes, and at times, may be associated with poorer outcomes.63-65 Given this, we recommend a decreased focus on utilization as an outcome and suggest that if utilization is included as an outcome, it is either specific to the type of care received (e.g., receipt of evidence-based care) or linked to patient-level outcomes. Finally, research on patient-level outcomes must be priority in the future. Such work will be challenging because there are a number of variables might impact both access and outcomes (e.g., comorbidities). Thus, rigorous, highly controlled research will be needed to ensure that increased access is resulting in improved health for veterans.