# RESULTS

## LITERATURE FLOW

The OVID MEDLINE search yielded 209 references with 10 duplicates for a total of 199 unique references. The CINAHL search yielded 212 additional references and the PsycINFO search yielded 252 additional references. When the results from these searches were combined there were 663 titles and abstracts for review. From the 663 titles and abstracts, 553 references were excluded. The full text of 110 references was then reviewed and another 74 references were excluded. By hand searching reference lists from relevant articles we identified another 4 references and 9 articles were identified by a TEP member or reviewer. A total of 49 articles were included. Figure 2 details the exclusion criteria and the number of references related to each of the key questions.

Figure 2 Literature Flow Diagram (for Key Questions 1 and 2)

## KEY QUESTION #1 WHAT IS THE EVIDENCE THAT VARIATION IN VETERANS' ABILITY TO OBTAIN NEEDED HEALTH CARE (I.E., ACCESS) CONTRIBUTES TO VARIATION IN SYSTEM-LEVEL (E.G., UTILIZATION, SATISFACTION) OR PATIENT-LEVEL (E.G., QUALITY OF LIFE, FUNCTIONAL ABILITY, MORTALITY) OUTCOMES?

We identified 23 studies representing 22 datasets that looked at the impact of access on system-level or patient-level outcomes (see Appendix C, Table 1). There were 9 cohort studies and 14 cross-sectional studies. Four studies were of good quality,9-12 13 were of fair quality,13-25 and six were of poor quality.26-31 Sample sizes in the 23 studies ranged from 109 to 3,424,699. Twenty studies enrolled veterans exclusively. In one study, 98.5% of the patients were veterans,18 in a second study 30.5% of the participants were veterans,31 in a third study 17% were veterans.26 Twenty-two studies reported gender. Four of those studies included only males. In the remaining 18 studies, 93% to 98% of the participants were male. Twenty-one studies also reported age. Mean age in 11 studies that enrolled patients 18 years and older ranged from 43 to 59 years. In two studies from the same dataset that enrolled only patients 65 years and older, the mean age was 78 years. Two studies reported median age with a median of 75 years in a study that enrolled only patients age 65 and older and a median of 34 years in another study. Six studies reported number of participants in specified age intervals. Race or ethnicity data were reported in 18 studies. One study included only Native American veterans. In the remaining studies, 29% to 88% were Caucasian (reported in 13 studies), 9% to 54% were African-American (13 studies), 3% to 28% were Hispanic (4 studies), and 1% were Native American (1 study). Between 1% and 92% were reported as Other (4 studies), and 7% and 10% were Unknown (2 studies). One study reported Hispanic and non-white race/ethnicity by age and VA use categories.

Many factors can impact veterans' ability to obtain needed care. Distance to VA facilities, wait times for appointments, ability to pay for care (considering income, disability, and service connection), social support, severity of illness/comorbid conditions, and access to other care (via Medicare or private insurance) have all been investigated. In the following sections we report the evidence regarding the impact of these factors on system-level and patient-level outcomes organized by clinical service area.

### SYSTEM-LEVEL OUTCOMES

System-level outcomes, including utilization, admission, and readmission, were reported in 22 studies including 8 cohort studies and 14 cohort studies. Fifteen of the studies (14 datasets) analyzed data from national VA datasets or surveys. Three studies were of good quality, 13 were of fair quality, and 6 were of poor quality.

Outpatient services: Data from a national survey of veterans highlighted decreased use of outpatient services as distance from a VA facility increased.13 The greatest decrease in utilization was noted for distances up to 60 miles with little change beyond. For veterans who chose to use the VA for some outpatient services, distance from the facility had a smaller additional effect on the number of visits. Increased use of VA physical and mental health services was noted for Vietnam veterans living on American Indian reservations located closer to VA facilities (in the Northern Plains region) compared to veterans living on a reservation located further from VA facilities (in the Southwest region).29 In a nationwide study of 8,983 veterans with spinal cord injuries and disorders, use of VA outpatient services decreased as distance from a VA facility increased. Increased age, non-white race, and a history of major illness were associated with increased utilization.20 Non-metropolitan VA patients between 18 and 44 years old were more likely (p<0.005) to report that they needed to see a doctor but could not because of cost than metropolitan VA patients or non-VA patients, or non-veterans of the same age. Among 45 to 64 year olds, VA patients, regardless of residence, were more likely to report cost as a factor than non-VA patients or non-veterans.31

Veterans and non-veterans with human immunodeficiency virus (HIV) reported problems with transportation time (greater than 1 hour [17%] or greater than 30 minutes [55%]) and location (34%). In addition to travel barriers, patients with HIV also reported problems with office hours (48%), wait time for urgent appointments (greater than 2 days [23%] or greater than 1 day [50%]), office wait time (greater than 2 hours [32%] or greater than 1 hour [54%], and cost of care (49%).26

Homeless veterans in 9 states who had serious mental illness were more likely to use VA services if they resided in cities with VA medical centers or hospitals, if they had service-connected disabilities, or if they received non-service connected VA pensions.27 A regional study that enrolled homeless veterans found increased use of VA services among those living in metropolitan areas and among those receiving financial support though the Department of Veterans Affairs.28

Patients who were discharged following treatment for acute myocardial infarction (MI) were less likely to receive outpatient care within 30 days or within 90 days if they lived more than 20 miles from the admitting hospital. The analysis was based on data from over 4,000 veterans nationwide. Other factors associated with increased likelihood of receiving outpatient care within 30 days were service connected disability, age over 55 years, comorbid conditions, discharge from a teaching hospital, and revascularization procedure while a history of alcohol abuse was associated with decreased likelihood. A similar pattern was seen for the likelihood of one or more visits within 90 days except that alcoholism, type of hospital, and comorbidity were not related.10

Three large studies (2 that used data from national datasets, 1 that used data from 33 VA treatment programs) evaluated use of VA care following inpatient treatment for alcoholism, psychiatry, and / or substance abuse.9,14,25 Patients who lived closer to VA facilities were more likely to attend an aftercare appointment9,25 and were more likely to use outpatient medical services.14 Urban residing (with distance held constant) and unmarried patients were less likely to attend aftercare for alcohol dependence.9 Patients receiving VA compensation payments, those with a psychiatric diagnosis (as opposed to substance abuse), and those who had mental health follow-up within 30 days of discharge were also more likely to have received outpatient medical services following an inpatient stay for psychiatry or substance abuse.14 Older age, married status, service-connected eligibility, psychiatric comorbidity, substance use disorder, and being a patient at a teaching hospital were associated with increased likelihood of receiving aftercare following inpatient substance abuse care; medical comorbidities were associated with decreased likelihood.25

Three studies presented data on patients receiving mental health care. In a study that enrolled veterans receiving mental health services at 2 VA mental health centers, increased outpatient use of mental health services was associated with fewer reported access problems and no social support although the greatest predictor of use was clinical need.16 Among patients (nationwide) with bipolar disorder, schizophrenia, or other psychoses, the number of psychiatric and non-psychiatric outpatient visit days decreased as distance from the VA outpatient service increased. Patients who had initial contact at a non-psychiatric clinic, a higher comorbidity rating, or resided in a rural area had fewer outpatient psychiatric visit days while those who were older, married, female, rural, had an initial visit at a non-psychiatric facility, or had a higher comorbidity rating had more outpatient non-psychiatric visit days.21 In a similar population, an increased risk of a 12 month gap in VA health system utilization was associated with residence a greater distance from a VA facility, homelessness, and a recent inpatient stay while a decreased risk of a 12 month gap was associated with residence in a county with greater availability of VA inpatient beds, older age, female gender, married status, VA service connection, higher comorbidity score, and a diagnosis of schizophrenia. An increased risk of a 12 month gap in mental health services was associated with residence a greater distance from VA psychiatric services, increased age, female gender, homelessness, higher comorbidity score, and recent inpatient stay. A decreased risk of a gap in mental health services was associated with married status, VA service connection, and a diagnosis of schizophrenia.22

Use of VA or non-VA health and mental health services was the focus of three additional studies. In one study, with data from over 1.4 million outpatients, there was an increase in the exclusive use of a VA facility as distance from the facility decreased. There was also greater exclusive use of outpatient VA facilities among patients with a higher VA priority designation and those living in counties with a higher level of poverty. Urban residents and those living in counties with a higher number of hospital beds were less likely to rely exclusively on VA care.19 A second study, with over 20,000 survey respondents, reported increased use of VA outpatient health and mental health services among those younger, unmarried, unemployed, and lacking health insurance. Greater use of VA health services (but not mental health services) was also associated with VA disability rating and poorer physical health. Non-VA health visits were associated with older age, female gender, college education, unemployment, disability rating and poorer physical and mental health. Non-VA mental health visits were associated with younger age, female gender, college education, unmarried status, unemployment, urban residence, and poorer physical and mental health.15 The third study, with data from over 1.9 million veterans, reported increased reliance on VA care (outpatient and overall) if the differential distance (distance from residence to VA facilities and non-VA facilities) was lower. There was also greater reliance on VA care by veterans with disability or low income priority classifications and those with mental health or substance abuse conditions.24

Inpatient services: One study focused on facility wait time for care and admission for an ambulatory care sensitive condition (ACSC) such as asthma, diabetes, or chronic obstructive pulmonary disease. Hospitalization for an ACSC would likely be avoided if the patient were to receive appropriate outpatient care in a timely manner. The analysis included data from 33,431 veterans age 65 and older who visited a geriatric outpatient clinic. The probability of admission for an ACSC was significantly greater (p<0.05) for veterans who visited facilities with wait times of 29 days or more compared to visits to facilities with wait times of less than 22.5 days. Age, previous ACSC hospitalization, higher comorbidity index, and diagnosis of cancer or endocrine, heart, or pulmonary disease were also associated with increased risk of hospitalization.12

Patients who presented for emergency psychiatric care at one VA facility were more likely to be admitted for treatment if they lived more than 60 miles from the facility. Age greater than 65 years and lower score on the Global Assessment of Functioning (GAF) were also associated with increased likelihood of admission.17 A study based at 2 VA mental health centers found that increased inpatient hospitalization for mental health services was associated with homelessness although the greatest predictor was clinical need.16

Veterans with spinal cord injuries and disorders had lower inpatient utilization if they lived a greater distance from the facility while history of major illness was associated with increased inpatient utilization.20

The impact of access to care on readmission was reported in two studies. Increased distance, expressed as “close,” “medium,” or “far,” from the county where the VA admitting facility was located, was associated with a non-significant, incremental, 18% increase in the risk of early (within 30 days) readmission. The veterans enrolled in this study were discharged from the internal medicine, surgery, intermediate care, or neurology services. The probability of readmission was also increased if the patient had two or more surgeries or their readmission risk was rated above “very low.”18 Using national VA databases, distance to care was not associated with an increased risk of readmission following treatment for MI. Age greater than 65 years, comorbid conditions, and receipt of any VA ambulatory care within 90 days were associated with increased risk of readmission.10

Three studies explored choice of VA or non-VA inpatient services. An analysis of data from over 400,000 veterans with inpatient admissions yielded results similar to those observed for outpatient utilization notably decreased exclusive use of VA services as distance to the VA increased. Age, urban residence, VA priority level, and poverty level were also factors associated with choice of inpatient services.19 A study of over 2 million hospital admissions for any of 14 high-risk elective surgeries among veterans 65 years or older found that 89% of heart surgeries, 85% of vascular surgeries, and 79% of cancer resections were performed in non-VA hospitals with little difference based on place of residence. The study also differentiated high performing from low performing hospitals and reported that, regarding travel time to high performing hospitals, urban residents had the least travel burden.31 Data from over 1.9 million veterans suggested that patients with transplant and amputation aggregated condition categories (ACCs) were more likely to rely on the VA for inpatient care. Other ACCs associated with inpatient VA care included infectious and parasitic disorders, substance abuse, mental health disorders, and eye disorders.24

Pharmacy utilization: One study evaluated use of VA pharmacy services. The nationwide study included veterans enrolled in both VA and Medicare programs. Enrollment in a Medicare plan with pharmacy benefits, age over 65 years, income of $20,000 or greater, female gender, VA priority status requiring copayment for medications, Medicare state buy-in, resident of a metropolitan statistical area, and being a patient at a teaching hospital were associated with decreased likelihood of using a VA pharmacy. Veterans of Hispanic race and of poorer health status were more likely to use the VA pharmacy.23

### PATIENT-LEVEL OUTCOMES

In contrast to system-level outcomes, patient-level outcomes, including mortality, perceived health, and quality of life, were only reported in 5 studies. Three were cohort studies (two of good quality, one of fair quality) and 2 were cross-sectional studies (both of fair quality).

Two nationwide studies evaluated mortality.10,11 Patients discharged following hospitalization for MI and living more than 20 miles away from the admitting hospital had a significantly higher risk of dying within 1 year compared to individuals living within 20 miles. Age greater than 55 years and presence of comorbid conditions were also associated with increased risk of mortality while undergoing revascularization or receiving VA ambulatory care within 90 days after the index visit was associated with decreased risk of death.10 Based on the dataset of veterans 65 years of age and older who were seen for outpatient geriatric services at VA medical centers (Prentice, 2008), patients who visited facilities with wait times of 31 days or longer had a higher risk of death within 6 months than those who visited facilities with wait times of less than 31 days. Other factors significantly associated with increased risk of mortality included increased age, 50% or greater service connected disability, preventable hospitalization, higher comorbidity index, or diagnosis of cancer or endocrine, neurological, psychiatric, pulmonary, or “other” disease. Female gender was associated with decreased risk of mortality.11

Two smaller studies examined the impact of access on either quality of life in individuals with human immunodeficiency virus (HIV) or mental health among patients receiving mental health services. In 205 veteran and non-veteran patients with HIV, better overall health related quality of life (HRQOL) was associated with better perceived access to care (p<0.01). Included in the perceived access measure were affordability, availability, and convenience of care along with accessibility of specialists. The relationship between HRQOL and temporal access (transportation and waiting times) was not significant26. In another study, treatment access was not associated with mental health outcomes (Global Assessment of Function or Behavior and Symptom Identification Scale-24) among 421 patients receiving mental health services at 2 VA sites.16

Self-reported health and days of poor health in the preceding 30 days were reported in one study of over 45,000 veterans and non-veterans. The poorest health was reported by veterans currently in VA care, in particular, non-metropolitan residents age 45 and older. Veterans in VA care, regardless of residence, reported a higher number of days of poor health (physical, mental, or limiting activities) in the past 30 days when compared to veterans not in VA care or non-veterans.30

## KEY QUESTION #1A DOES THE EFFECT OF ACCESS ON SYSTEM AND/OR PATIENT LEVEL OUTCOMES DIFFER BY PATIENT, TREATMENT, OR SETTING CHARACTERISTICS?

Six studies evaluated the effect of interactions on system level factors.9,13,21,24,26,28 All but one of the studies26 included either a national sample of veterans13,21,24,28 or veterans treated at multiple sites.9 There were two cohort studies (one of good quality and one of fair quality) and four cross-sectional studies (two of fair quality and two of poor quality).

The effect of distance on the number of outpatient visits, both psychiatric21 and non-psychiatric13,21, as well as reliance on VA care24 was greater for older patients. Patients with a diagnosis of schizophrenia were also more affected by distance than those with bipolar disorder.21 Among patients scheduled to attend an aftercare appointment within 30 days following an inpatient alcohol dependency program, older patients and those with a rural residence were more negatively impacted by distance.9 On a scale of 0 (worst possible access) to 100 (best possible access), the access scores for transportation time to appointment were lower for patients infected with HIV and who had VA insurance compared to those who had California Medicaid insurance (p<0.05). The access scores for covering cost of care and availability of hospital care were higher for VA patients than for uninsured (non-VA) patients while the scores for office wait time and availability of emergency care were higher for VA patients than for uninsured or California Medicaid patients (all p<0.05).26 Among homeless veterans, the effect of metropolitan/ non-metropolitan status on use of VA facilities varied based on age, military service era, monthly income, time homeless, and past alcohol or drug dependency.28

## KEY QUESTIONS #2 AND #2A WHAT INTERVENTIONS HAVE BEEN SUCCESSFUL IN IMPROVING ACCESS FOR PATIENT POPULATIONS WITH REDUCED HEALTH CARE ACCESS? HAVE INTERVENTIONS THAT HAVE IMPROVED HEALTH CARE ACCESS LED TO IMPROVEMENTS IN SYSTEM LEVEL AND PATIENT LEVEL OUTCOMES?

We identified 26 articles (24 unique studies) that assessed interventions designed to improve veterans' access to healthcare (see Appendix C, Table 2). We only included articles that provided data regarding the intervention's impact on actual access (observable, measurable dimensions), perceived access (self-reported, subjective dimensions), or satisfaction with access.1 During abstraction, we found that the articles reported on six distinct types of interventions. The results are grouped by those interventions.

### COMMUNITY BASED OUTPATIENT CLINICS (CBOCs)

#### Detailed Description

In order to increase access to primary care for veterans living in rural or other underserved geographical areas, the VA began opening satellite primary care clinics, known as CBOCs. Four of the articles32-35 utilized quasi-experimental designs to examine the impact of the opening of CBOCs on access factors. All four studies found that the opening of CBOCs had a positive impact on geographic accessibility as evidenced by the CBOCs attracting more users new to the VA than VA Medical Centers (VAMCS), a decrease in travel distance to the closest VA facility for those in CBOC catchment areas, and higher rates of accessing VA medical services in counties with a CBOC. A number of system-level outcomes were also identified. It was found that CBOC patients had more primary care visits and that decreases in travel distance significantly predicted increases in the number of primary care encounters.

Findings regarding the utilization of specialty care were mixed. Fortney et al.32 found that CBOC patients had fewer specialty care encounters, while Fortney et al.33,34 found that those in CBOC catchment areas had more ancillary and extended care physical health visits. Finally, in counties with CBOCs that offered specialty mental health services, more veterans accessed mental health services. Importantly, CBOCs did not have a significant impact on a number of access and system-level outcomes (e.g., days between discharge and outpatient follow-up, hospital admissions, inpatient days) and the impact on some system-level outcomes were small and may not be clinically significantly. For example, Fortney et al.33 reported that those in the CBOC catchment area only had 0.5 more primary care visits in the 18-months post-implementation than pre-implementation. None of the studies provided data on patient-level outcomes.

It is important to note that while these studies found that CBOCs had a positive impact on geographical access, a vast majority of veterans residing in catchment areas (approximately 85%) still did not receive VA care.35 However, data suggest that high priority groups (those with service-connection or chronic diseases) may be experiencing greater benefits from the opening of CBOCs. For example, veterans in CBOC catchment areas with alcohol-related and hypertension diagnoses attended more primary care visits, while those with diabetes attended more mental health and ancillary services than veterans not in a CBOC catchment area33. Further, Rosenheck et al.35 found that veterans who were service-connected for any disorder (7.6% increase for those with no new CBOCs; 9.6% increase for those with new CBOCs) and those who were service-connected for non-mental health problems (7.3% increase for those with no new CBOCs; 9.4% increase for those with new CBOCs) had a significant increase in VA services. Finally, three studies found that CBOC veterans differ from VAMC veterans on demographic factors; those at CBOCS were found to be older, more often male, more often Caucasian, less often African American or Hispanic, more often married, and less often service connected than veterans seen at the parent VAMCs.

Two studies examined veterans' satisfaction with access and other aspects of care at CBOCs. Borowsky et al.36 reported that veterans using CBOCs reported better access / timeliness and were more likely to report waits of less than 20 minutes than veterans getting care at VAMCs. Further, veterans using CBOCs more often reported having good or excellent visits and reported fewer problems with their visits. Morgester et al.37 examined differences in veterans who received care from a CBOC, those who lived in a CBOC catchment area who did not use VA care, and those who received care from a VAMC. All three groups reported few access problems; they had few problems finding the clinic, found the hours of operation convenient, and were satisfied with care. Although no statistical comparisons were conducted, differences between the three groups were small. No patient-level outcomes were reported for either study.

#### Summary of findings

We identified six studies that examined the impact of the opening or use of CBOCs on veterans' access to health care. None of the studies were randomized trials, although four utilized quasi-experimental designs in which cohorts were compared both pre- and post-implementation. Overall, the sample sizes were large, with one being VA-wide. Four of the studies were of fair quality, while 2 were poor quality. The overall strength of the evidence was poor.

All six studies found that CBOCs had a positive impact on various measures of access; four studies found an association between the opening of CBOCs and objective measures of access to primary care while two studies found that veterans were satisfied with CBOCs' accessibility. Five of the studies reported system-level outcomes. Overall, increased access was associated with increased primary care use, while findings regarding specialty care were mixed. No studies reported patient-level outcomes.

### PRIMARY CARE MENTAL HEALTH INTEGRATION

#### Detailed Description

Two articles examined the impact of integrating mental health services into a primary care clinic, with the specific goal of improving access and outcomes for veterans with depression.38,39 Watts et al.39 conducted a quasi-experimental study examining a primary care clinic before and after the PCMH integration at a VAMC and associated CBOCs. The mental health services involved co-location of mental health services in the primary care clinic, collaborations between the primary care and mental health staff, advance or open access to mental health providers within the primary care clinic, and the use of standardized instruments for the assessment of mental health conditions. After PCMH integration, they found that more veterans at the VAMC received care for depression and fewer veterans received no depression treatment. Further they found that more veterans received care in mental health clinics and wait times for an appointment in the mental health clinics decreased substantially. None of these differences were significant at the CBOCs. In regard to systems outcomes, more veterans at the VAMC received “optimal depression treatment” following integration. No patient-level variables were reported. Shiner et al.38 reported on the effect of implementing five differing models of PCMH integration at one VAMC and four CBOCs. At the VAMC, the PCMH integration model was the same as described above. CBOC-A offered walk-in access one day per week, assessment by both a psychotherapy and psychopharmacologically oriented provider, and standardized assessments. CBOC-B had a psychotherapist on the primary care team and had back-up telepsychiatry services by appointment. CBOC-C did not have PCMH integration, but had a mental health clinic on-site. CBOC-D did not offer mental health services. Following implementation, the VAMC and CBOC-A had nearly identical results, with both experiencing increases in the number of veterans receiving mental health care in four days and 30 days, and the number of veterans receiving optimal care. The less intensive CBOC-B also had an increase in the number of veterans receiving care within 30 days and the number of veterans receiving optimal care. There were no differences for CBOC-C or CBOC-D. No system- or patient-level outcomes were assessed.

Two articles examined implementing primary care clinics into existing mental health / substance use clinics.40,41 Druss et al.40 conducted a randomized trial to examine the efficacy of implementing a primary care in the mental health clinic. In regard to access, veterans randomized to PCMH integration reported significantly better satisfaction with access to care. The two conditions also yielded significant differences on a number of systems-level variables; those in PCMH integration had more primary care visits, fewer ER visits, received more preventive services, and reported greater satisfaction across a number of domains. Finally, in regard to patient-level outcomes, veterans assigned to PCMH integration had better physical component SF-36 scores at one-year post randomization; there was no difference on the mental component score. Saxon et al.41 conducted a similar study in which they randomized veterans receiving care in a substance use clinic to receive primary care from a clinic located within the substance use clinic or through a medical clinic (treatment as usual). The integrated condition fared better on measures of access, including length of wait for initial primary care visit, odds of attending a rescheduled initial visit, and the likelihood of attending at least one primary care visit. However, there was no difference on the likelihood of attending the initially scheduled appointment. In regard to system-level outcomes, those assigned to PCMH integration condition were more likely to attend return primary care visits and had more primary care visits during the study period, were less likely to seek non-VA care, and were more likely to remain engaged in substance use treatment at 60 days (although not at 6 or 12 months). Mean days in substance use treatment did not differ. There were no sustained differences in ER visits or hospital admissions. There were no group differences on patient-level outcomes, including the SF-36 (both physical and mental composite scores) or substance use disorder outcomes.

Finally, one study reported on the effort to integrate primary care, mental health, and services for homeless veterans.42,43 The quasi-experimental design compared homeless veterans with substance use problems and serious mental illness both before and after the opening of the integrated clinic. Within the integrated clinic, veterans were evaluated in a screening clinic and quickly referred to other services, all of which were housed within the same building. The goal was to have the primary care appointment occur on the day of screening. The intervention did result in shorter wait times for an initial primary care appointment; the PHMC integration group had, on average, less than a day lapse, while the usual care group waited approximately 2 months for their initial visit. In regards to system-level outcomes, the PCMH group received more preventive services, had a higher number of primary care visits, and had lower levels of ER use. There were no differences in rates of admission, inpatient days, or the number of veterans receiving primary care. There were no significant differences in the patient-level variable of physical health status.

#### Summary of Findings

We identified six articles (five unique studies) that examined the impact of primary care mental health (PCMH) integration on veterans' access to health care services. Two studies examined the integration of primary care into mental health clinics; two examined the integration of mental health into primary care clinics; and one study (two articles) examined the integration of mental health, primary care, and homeless services. Two of the studies were randomized trials, the others were quasi-experimental. The overall strength of the evidence was poor; one study was of high quality, two of fair quality, and three were low quality.

All five found that integration led to improvements in objective or self-reported access. Two studies specifically examined access to optimal treatments and found that PCMH led to more veterans receiving optimal depression care. Three studies found associations between increased access and more primary care visits. Three studies reported on patient-level outcomes; results were mixed.

### INTENSIVE CASE MANAGEMENT

Two studies (one good, one poor quality) examined the effect of intensive case management on access.44,45 The overall strength of the evidence was poor. Both intensive case management programs had a number of goals, including increasing access to needed services for veterans already within the VA system who had high levels of health care needs. Ritchie et al.44 examined the impact of the Coordination and Advocacy for Rural Elders (CARE) program, which was designed to improve the health and functioning and to extend the length of independent living for elderly rural veterans. This is done, in part, through increasing access to health services. Veterans in the care program received multiple, standardized assessments through which a provider identified problems, developed a care plan, and tracked the resolution of problems. In regard to access, it was found that over 56% of veteran received a medical referral or linkage following the assessments. No system- or patient-level outcomes were assessed.

Weinberger et al.45 conducted a randomized trial in which hospitalized veterans with diabetes, chronic obstructive pulmonary disease, or congestive heart failure, who did not have ongoing primary care, were assigned to either treatment as usual or an intensive primary care program. The primary care program was designed to increase access to primary care through both inpatient and outpatient components. While the veteran was still in the hospital, a primary care doctor and nurse each made visits to assess current functioning and post-discharge needs, and the primary care nurse made an appointment for the veteran to visit the primary care clinic within one week of discharge. Following discharge, the nurse called the veteran within two days to assess any problems and to remind the veteran of his upcoming appointment. Appointment reminders were sent and missed-visit protocols were implemented as needed. During the first primary care appointment, both the nurse and doctor reviewed and updated the treatment plan. In regard to access, the data showed that the median time from hospital discharge to primary care was shorter and self-reported satisfaction with access was higher for the intervention group. The two groups differed on system-level outcomes, with intervention veterans being more satisfied with care, more likely to visit a general medicine clinic, and less likely to visit specialty care. Surprisingly, those in the intervention condition were more likely to be readmitted to the hospital, readmitted sooner, and have more days of rehospitalization. There were no differences on patient-level outcomes (SF-36).

### TELEMEDICINE

#### Detailed Descriptions

Two studies (a cohort study and a RCT) examined the efficacy of using telemedicine as a method for patients to communicate with existing providers.46,47 Barnett et al.46 examined the use of telehealth messaging in older, at-risk, veterans with type two diabetes, while Hopp et al.47 conducted a randomized trial to determine the impact of telehealth messaging on veterans receiving home care services. Both telehealth programs involved the veteran updating the nurse on current symptoms and problems via the telehealth device, which transmitted both video and sound. In the Hopp et al.47 study, some units also had monitoring devices (e.g., blood pressure cuffs), which would directly transmit data to the nurse. During the telehealth sessions, the nurse could have discussed concerns with the veteran, provided disease management suggestions, made referrals as appropriate, and reminded the veteran to continue with his treatment plan (e.g., take medication, exercise). The telehealth programs appeared to have a positive impact on access; Hopp et al.47 reported that contacts with VA providers increased and Barnett et al.46 found that care-coordinator initiated primary care visits increased by 8.9% following the implementation of telehealth. However, the findings regarding outcomes were less promising. Hopp et al.47 did not find any group differences in system-level outcomes (e.g., satisfaction, utilization variables); neither did Barnett et al.46 after controlling for baseline A1c levels. Hopp et al.47 did find that the intervention group had better scores on the mental component summary of the Health Related Quality of Life Scale as compared to the treatment as usual group; no other patient-level variables were significant (e.g., physical component score).

The other two telemedicine studies examined the utility of telemedicine in receiving specialty care consultations from off-site providers. Wakefield et al.48 examined the use of telehealth to receive a variety of specialty consultations from specialists at a VAMC for veterans in a long term care facility, while Wilkins et al.49 evaluated the feasibility of using telehealth to receive consultation from a multidisciplinary wound care team for veterans at a VAMC without such a team. In both studies, the veterans reported that telemedicine was easier and more convenient than travelling to meet with a specialist and a large majority of veterans were satisfied with telemedicine. No system- or patient-level outcomes were assessed.

#### Summary of Findings

We identified four studies that examined the use of telemedicine. Two studies were of fair quality and two were of poor quality, leading to an overall rating of poor. Two studies examined the efficacy of using telemedicine as a method for patients to communicate with existing providers,46,47 while two studies examined the use of telemedicine to consult with off-site specialists.48,49 One of the studies was an RCT of fair quality, the other three were non-experimental designs. Two studies found that veterans found telemedicine to be as, or more, convenient than in person appointments and two found that the use of telemedicine was associated with increased access / referrals to providers. One study47 (the RCT) examined patient-level outcomes; the intervention had a positive impact on the mental component of the health-related quality of life scale.

### OUTREACH

One fair-quality RCT examined the impact of outreach efforts on veterans' access to health care. McFall et al.50 conducted a randomized trial in which Vietnam veterans who were service-connected for posttraumatic stress disorder (PTSD) were either randomized to the outreach intervention or to a no-intervention control. Those in the intervention condition received a mailing which included information regarding PTSD treatment services and contained a letter from the director of the PTSD program inviting them to seek care and providing them with three options for responding (return a postcard, call the study coordinator, or come to the walk-in clinic). The second component of the intervention was a direct phone call to the veteran by the study coordinator. The primary purpose of the call was to inquire about barriers to seeking care, but the study authors deemed it as part of the intervention because during the phone call, veterans could ask about services, discuss and address barriers to care, or schedule an appointment. The outreach did have a positive impact on access; more veterans in the outreach condition scheduled (19% vs. 7% of the intent-to-treat sample) and presented (approximately 15% vs. 7%) for an intake session. In addition, they were more likely to attend at least one follow-up session. No patient-level outcomes were assessed.

### COPAYMENTS

#### Detailed Descriptions

While the VA is generally considered an open-access healthcare system in which cost does not present a significant barrier, an increase in medication copayment rates from $2 to $7 provided a unique opportunity to examine the impact of copayments on access to needed medications within the VA. We identified four cohort studies that examined the impact of the copayment increase on (a) veterans with prescriptions for diabetic, hypertensive, or hyperlipidemic medications,51 (b) veterans with a diagnosis of schizophrenia or schizoaffective disorder,52 (c) veterans on lipid-lowering medications53, and (d) a random sample of VA pharmacy users.54 Maciejewski et al.51 found that while adherence was similar between veterans with and without a copayment prior to the cost increase, afterward, veterans with a copayment were significantly less adherent than veterans without a copayment (60% vs. 69% for those with diabetes and 76% vs. 80% for those with hypertension at the end of the study). Similarly, among veterans using lipid-lowering medications, while lipid-medication use decreased overall during the course of the study, the decrease was more pronounced in those with a copayment53. Zeber et al.52 found that copayments had a negative impact on adherence. For total prescriptions (medical and psychiatric) and medical prescriptions, while both the copayment exempt and non-exempt groups increased their use of medications over the study period, the non-exempt group did so at a significantly slower rate. For psychiatric medications, those exempt from copayments increased their use throughout the study period, while those with a copayment decreased their use nearly 25% following the price increase. Further, veterans with a copayment were 5% more likely to have a psychiatric admission following the price increase. Finally, Stroupe et al.54 found that among a random sample of VA pharmacy users, those with a copayment received 8% fewer 30-day refills than those without payments.

#### Summary of Findings

We identified four studies that examined the impact of the copayment increase on veterans' adherence to medications. All four studies were of fair quality and the overall strength of evidence was fair. All of the studies found that increases in medication copayments led to decreases in medication adherence. One study52 examined system-level outcomes and found that following the price increase, veterans with a copayment had a greater increase in the rate of psychiatric hospitalization than copayment exempt veterans. No studies reported patient-level outcomes.

### OTHER ACCESS INTERVENTIONS

We identified three additional studies that examined the effect of intervention on access. All three studies were of poor study quality. Two of those examined access to specific medical services: treatment for hepatitis55 and specialty rehabilitation care following a lower-extremity amputation.56 Hagedorn et al.55 implemented a Healthy Liver Program (the goal of which was to increase access to the prevention, identification, and treatment of hepatitis) into a substance abuse clinic. The intervention included testing for all veterans at the time of intake, scheduling veterans who were entering the clinic into an educational healthy liver group, administration of vaccinations, and referrals to the hepatitis clinic as necessary. Following the intervention, testing for hepatitis increased significantly and 94% of appropriate veterans started a vaccine series. Approximately 86% of veterans complied with a 1-month booster requirement and 60% complied with the 6-month booster. In regard to system-level outcomes, 78% of those who learned they had hepatitis attended their intake at the hepatitis clinic.

Bates et al.56 examined differences in rates of referral and outcomes for veterans with a lower-extremity amputation who were at VAMCs with and without Specialized Rehabilitation Units (SRUs). The SRUs are multidisciplinary specialty teams which were hypothesized to increase awareness toward rehabilitation, which would increase access to helpful rehabilitation services. Contrary to expectations, Bates et al.56 found that the presence of a SRU did not increase the likelihood that a veteran would be referred for rehabilitation services, however, those within a SRU VAMC were more likely to receive specialty, rather than general rehabilitation.

Finally, Rodriguez et al.57 conducted a qualitative study to examine elderly African American veterans' reaction to a mobile geriatric care unit (MGU). The MGU was a vehicle with a check-in area, bathroom, patient education room, and examination room equipped to perform standard preventive care. The qualitative analyses revealed that veterans commented on the accessibility of care 26 times in 18 interviews. The comments were related to geographic proximity, hours of operation, and wait time. In regard to system-level outcomes, veterans mentioned quality of care 28 times. No patient-level outcomes were assessed.