# REFERENCES

1 Fortney J. A re-conceptualization of access for 21^st^ century healthcare. Oral presentation given to the VA Health Services Research & Development Service Timely Topics of Interest Cyber Seminar Series. August 2010.
2 Mayo-Smith MF. Access issues within VA offer challenges, research opportunities. FORUM, VA Health Services Research & Development Service. July 2008.
3 Weeks WB. Access to care: a VA research agenda. FORUM, VA Health Services Research & Development Service. July 2008.
4 Agency for Healthcare Research and Quality. 2007. National Healthcare Disparities Report. Rockville, MD. U.S. Department of Health and Human Services, Agency for Healthcare Research and Quality. AHRQ Pub. No. 08-0041, February 2008.
5 Demakis JG. Rural health-improving access to improve outcomes. Management Brief, Health Services Research & Development Service. Jan. 2000;(No. 13):1-3.
6 Institute of Medicine Committee on Monitoring Access to Personal Health Care Services. Access to health care in America. Millman M, editor. Washington, CD. National Academy Press. 1993.
7 Miller LJ. Improving access to care in the VA health system: A progress report. FORUM, VA Health Services Research & Development Service. June. 2001.
8 Harris RP, Helfand M, Woolf SH, et al. 2001. Current methods of the U.S. Preventive Services Task Force: A review of the process. Am J Prev Med. 2001;20(3S):21-35.
9 Fortney JC, Booth BM, Blow FC, Bunn JY, Loveland Cook CAl. The effects of travel barriers and age on the utilization of alcoholism treatment aftercare. Am J Drug Alcohol Abuse. 1995;21:391-406. [pmid: 7484987].
10 Piette JD, Moos RH. The influence of distance on ambulatory care use, death, and readmission following a myocardial infarction. Health Serv Res. 1996;31:573-91. [pmid: 8943991].
11 Prentice JC, Pizer SD. Delayed access to health care and mortality. Health Serv Res. 2007;42:644-62. [pmid: 17362211].
12 Prentice JC, Pizer SD. Wait times and hospitalizations for ambulatory care sensitive conditions. Health Serv Outcomes Res Methods. 2008;8:1-18.
13 Burgess JF Jr, DeFiore DA. The effect of distance to VA facilities on the choice and level of utilization of VA outpatient services. Soc Sci Med. 1994;39:95-104. [pmid: 8066492].
14 Druss BG, Rosenheck RA. Use of medical services by veterans with mental disorders. Psychosomatics. 1997;38:451-8. [pmid: 9314714].
15 Elhai JD, Grubaugh AL, Richardson JD, Egede LE, Creamer M. Outpatient medical and mental healthcare utilization models among military veterans: results from the 2001 National Survey of Veterans. J Psychiatr Res. 2008;42:858-67. [pmid: 18005993].
16 Fasoli DR, Glickman ME, Eisen SV. Predisposing characteristics, enabling resources and need as predictors of utilization and clinical outcomes for veterans receiving mental health services. Med Care. 2010;48:288-95. [pmid: 20355260].
17 Fortney JC, Owen R, Clothier J. Impact of travel distance on the disposition of patients presenting for emergency psychiatric care. J Behav Health Serv Res. 1999;26:104-8. [pmid: 10069145].
18 Holloway JJ, Medendorp SV, Bromberg J. Risk factors for early readmission among veterans. Health Serv Res. 1990;25:213-37. [pmid: 2109741].
19 Hynes DM, Koelling K, Stroupe K, et al. Veterans' access to and use of Medicare and Veterans Affairs health care. Med Care. 2007;45:214-23. [pmid: 17304078].
20 LaVela SL, Smith B, Weaver FM, Miskevics SA. Geographical proximity and health care utilization in veterans with SCI&D in the USA. Soc Sci Med. 2004;59:2387-99. [pmid: 15450711].
21 McCarthy JF, Blow FC. Older patients with serious mental illness: sensitivity to distance barriers for outpatient care. Med Care. 2004;42:1073-80. [pmid: 15586834].
22 McCarthy JF, Blow FC, Valenstein M, et al. Veterans Affairs health system and mental health treatment retention among patients with serious mental illness: evaluating accessibility and availability barriers. Health Serv Res. 2007;42:1042-60. [pmid: 17489903].
23 Morgan RO, Petersen LA, Hasche JC, et al. VHA pharmacy use in veterans with Medicare drug coverage. Am J Manag Care. 2009;15:e1-e8. [pmid: 19298095].
24 Petersen LA, Byrne MM, Daw CN, Hasche J, Reis B, Pietz K. Relationship between clinical conditions and use of Veterans Affairs health care among Medicare-enrolled veterans. Health Serv Res. 2010;45:762-791. [pmid: 20403056].
25 Schmitt SK, Phibbs CS, Piette JD. The influence of distance on utilization of outpatient mental health aftercare following inpatient substance abuse treatment. Addict Behav. 2003;28:1183-92. [pmid: 12834661].
26 Cunningham WE, Hays RD, Williams KW, Beck KC, Dixon WJ, Shapiro MF. Access to medical care and health-related quality of life for low-income persons with symptomatic human immunodeficiency virus. Med Care. 1995;33:739-54. [pmid: 7596212].
27 Gamache GR, Rosenheck RA, Tessler R. Factors predicting choice of provider among homeless veterans with mental illness. Psychiatr Serv. 2000;51:1024-8. [pmid: 10913456].
28 Gordon AJ, Haas GL, Luther JF, Hilton MT, Goldstein G. Personal, medical, and healthcare utilization among homeless veterans served by metropolitan and nonmetropolitan veteran facilities. Psychol Serv. 2010;7:65-74. [pmid: 21152352].
29 Gurley D, Novins DK, Jones MC, Beals J, Shore JH, Manson SM. Comparative use of biomedical services and traditional healing options by American Indian veterans. Psychiatr Serv. 2001;52:68-74. [pmid: 11141531].
30 West A, Weeks WB. Physical and mental health and access to care among nonmetropolitan veterans health administration patients younger than 65 years. J Rural Health. 2006;22:9-16. [pmid: 16441331].
31 West AN, Weeks WB, Wallace AE. Rural veterans and access to high-quality care for high-risk surgeries. Health Serv Res. 2008;43:1737-1751.
32 Fortney JC, Borowsky SJ, Hedeen AN, Maciejewski ML, Chapko MK. VA Community-Based Outpatient Clinics: access and utilization performance measures. Med Care. 2002;40:561-9. [pmid: 12142771].
33 Fortney JC, Maciejewski ML, Warren JJ, Burgess JF Jr. Does improving geographic access to VA primary care services impact patients' patterns of utilization and costs?. Inquiry. 2005;42:29-42. [pmid: 16013585].
34 Fortney JC, Steffick DE, Burgess JF Jr, Maciejewski ML, Petersen LA. Are primary care services a substitute or complement for specialty and inpatient services?. Health Serv Res. 2005;40:1422-42. [pmid: 16174141].
35 Rosenheck R. Primary care satellite clinics and improved access to general and mental health services. Health Serv Res. 2000;35:777-90. [pmid: 11055448].
36 Borowsky SJ, Nelson DB, Fortney JC, Hedeen AN, Bradley JL, Chapko MK. VA community-based outpatient clinics: performance measures based on patient perceptions of care. Med Care. 2002;40:578-86. [pmid: 12142773].
37 Morgester WA, Biggs CJ. Community-based VHA clinics: effect on patient satisfaction and resource utilization. J Healthc Qual. 2002;24:34-8.
38 Shiner B, Watts BV, Pomerantz A, et al. Access to what? An evaluation of the key ingredients to effective advanced mental health access at a VA medical center and its affiliated community-based outreach clinics. Mil Med. 2009;174:1024-32. [pmid: 19891213].
39 Watts BV, Shiner B, Pomerantz A, Stender P, Weeks WB. Outcomes of a quality improvement project integrating mental health into primary care. Qual Saf Health Care. 2007;16:378-81. [pmid: 17913780].
40 Druss BG, Rohrbaugh RM, Levinson CM, Rosenheck RA. Integrated medical care for patients with serious psychiatric illness. Arch Gen Psychiatry. 2001;58:861-8. [pmid: 11545670].
41 Saxon AJ, Malte CA, Sloan Kl, et al. Randomized trial of onsite versus referral primary medical care for veterans in addictions treatment. Med Care. 2006;44:334-42. [pmid: 16565634].
42 Blue-Howells J, McGuire J, Nakashima J. Co-location of health care services for homeless veterans: A case study of innovation in program implementation. Soc Work Health Care. 2008;47:219-231. [pmid: 19042482].
43 McGuire J, Gelberg L, Blue-Howells J, Rosenheck RA. Access to primary care for homeless veterans with serious mental illness or substance abuse: a follow-up evaluation of co-located primary care and homeless social services. Admin Policy Ment Health. 2009;36:255-64.
44 Ritchie C, Weiland D, Tully C, Rose J, Sims R, Bodner E. Coordination and advocacy for rural elders (CARE): a model of rural case management with veterans. Gerontologist. 2002;42:399-405. [pmid: 12040143].
45 Weinberger M, Oddone EZ, Henderson WG. Does increased access to primary care reduce hospital readmissions? Veterans Affairs Cooperative Study Group on Primary Care and Hospital Readmission. New Engl J Med. 1996;334:1441-7. [pmid: 8618584].
46 Barnett TE, Chumbler NR, Vogel WB, Beyth RJ, Qin H, Kobb R. The effectiveness of a care coordination home telehealth program for veterans with diabetes mellitus: a 2- year follow-up. Am J Manag Care. 2006;12:467-74. [pmid: 16886889].
47 Hopp F, Woodbridge P, Subramanian U, Copeland L, Smith D, Lowery J. Outcomes associated with a home care telehealth intervention. Telemed J E Health. 2006;12:297-307. [pmid: 16796497].
48 Wakefield BJ, Buresh KA, Flanagan JR, Kienzle MG. Interactive video specialty consultations in long-term care. J Am Geriatr Soc. 2004;52:789-93. [pmid: 15086663].
49 Wilkins E, Lowery JC, Goldfarb S. Feasibility of virtual wound care. Adv Skin Wound Care. 2007;20:275-8. [pmid: 17473564].
50 McFall M, Malte C, Fontana A, Rosenheck RA. Effects of an outreach intervention on use of mental health services by veterans with posttraumatic stress disorder. Psychiatr Serv. 2000;51:369-74. [pmid: 10686246].
51 Maciejewski ML, Bryson CL, Perkins M, et al. Increasing copayments and adherence to diabetes, hypertension, and hyperlipidemic medications. Am J Manag Care. 2010;15:e20-34.
52 Zeber JE, Grazier KL, Valenstein M, Blow FC, Lantz PM. Effect of a medication copayment increase in veterans with schizophrenia. Am J Manag Care. 2007;13:335-46. [pmid: 17567234].
53 Doshi JA, Zhu J, Lee BY, Kimmel SE, Volpp KG. Impact of a prescription copayment increase on lipid-lowering medication adherence in veterans. Circulation. 2009;119:390-7. [pmid: 19139387].
54 Stroupe KT, Smith BM, Lee TA, et al. Effect of increased copayments on pharmacy use in the Department of Veterans affairs. Med Care. 2007;45:1090-7. [pmid: 18049350].
55 Hagedorn H, Dieperink E, Dignmann D, et al. Integrating hepatitis prevention services into a sub stance use disorder clinic. J Subst Abuse Treat. 2007;32:391-8. [pmid: 17481462].
56 Bates BE, Kurichi JE, Marshall CR, Reker D, Maislin G, Steineman MG. Does the presence of a specialized rehabilitation unit in a Veterans Affairs facility impact referral for rehabilitative care after a lower-extremity amputation?. Arch Phys Med Rehabil. 2007;88:1249-55. [pmid: 17908565].
57 Rodriguez KL, Appelt CJ, Young AJ, Fox AR. African American veterans' experiences with mobile geriatric care. J Health Care Poor Underserved. 2007;18:44-53. [pmid: 17337796].
58 Tuerk PW, Yoder M, Ruggiero KJ, Gross DF, Acierno R. A pilot study of prolonged exposure therapy for posttraumatic stress disorder delivered via telehealth technology. J Trauma Stress. 2010;23:116-23. [pmid: 20135675].
59 Bauer MS, McBride L, Shea N, Gavin C, Holden F, Kendall S. Impact of an easy-access VA clinic-based program for patients with bipolar disorder. Psychiatr Serv. 1997;48:491-6. [pmid: 9090732].
60 Bauer MS, McBride L, Williford WO, et al. Collaborative care for bipolar disorder: Part II. Impact on clinical outcome, function, and costs. Psychiatr Serv. 2006;57:937-45. [pmid: 16816277].
61 Boutelle KN, Dubbert P, Vander Weg M. A pilot study evaluating a minimal contact telephone and mail weight management intervention for primary care patients. Eat Weight Disord. 2005;10:e1-5. [pmid: 16682848].
62 Egede LE, Frueh CB, Richardson LK, et al. Rationale and design: telepsychology service delivery for depressed elderly veterans. Trials. Electronic Resource. 2009;10:22. [pmid: 19379517].
63 Fisher ES. Avoiding the unintended consequences of growth in medical care. JAMA. 1999;281:446-53. [pmid: 9952205].
64 Fisher ES. Medical care — is more always better?. N Engl J Med. 2003;349:1665-7. [pmid: 14573739].
65 Sirovich BE, Gottlieb DJ, Welch HG, Fisher ES. Regional variations in health care intensity and physician perceptions of quality of care. Ann Intern Med. 2006;144:641-9. [pmid: 16670133].