# PEER REVIEW COMMENTS AND AUTHOR RESPONSES

REVIEWER COMMENT | RESPONSE
1. Are the objectives, scope, and methods for this review clearly described?
Three specific comments about the search strategy:; a. The primary (or only) barrier to access that appears to be addressed in KQ1 was distance. However, there are numerous other relevant barriers and facilitators to access that I expected to be addressed in KQ1, including price/income, social support, health literacy, and access to other health systems (e.g., Medicare). These are all implied by the Potential Moderators in Figure 1, but only distance receives attention. A Medline search limited to “Health Services Accessibility” in Appendix A missed articles that address these issues, and studies that I expected to be included in KQ2.; b. It would be helpful to delineate whether specific types of studies were explicitly excluded or not considered for some reason. There may not have been such exclusion, but if so it should be mentioned.; c. Clear definitions of the seven types of interventions discussed in KQ2 would be informative for the reader who had some other studies in mind and wondered what category they would fall in. | a. Thank you for the suggestion. We revised the KQ1 section to highlight other barriers and facilitators to access. To re-do the search at this point would markedly expand the scope and practice.; b. The inclusion and exclusion criteria are outlined in the method section. We attempted to clarify that for KQ1, we included only studies that reported on how a measure of access impacted system-level or patient-level outcomes. Further, for KQ2, we included only studies that reported impact of the intervention on a measure of access (objective, subjective, or satisfaction with access).; c. We clarified that the types of interventions were not a priori categories used in the search, but rather, we developed after the search as a way to more cohesively present the findings. A brief description of each of the types of interventions is now presented in Table 2.
2. Is there any indication of bias in our synthesis of the evidence?
As mentioned in Comment #1 above, I expected to see a review of other barriers to access besides distance in response to KQ1. Not sure if it represents a bias per se. | As noted above, we revised the KQ1 section.
I expected there to be a number of studies reviewed in KQ2 that were not and it isn't clear to me why they weren't included. Not sure if it represents a bias per se.; a. In the section on CBOCs, I expected to see the following cites: Maciejewski et al. BMC HSR 2007, Liu et al. HSR 2010..; b. In the section on intensive case management, I expected to see Bosworth Ann Intern Med 2009 and Am Heart J 2009; Piette 2001 (diabetes); Heisler Ann Intern Med 2010; other self-management trials by VA researchers; c. The copay section should include papers by Stroupe Medical Care 2007 and Doshi Circulation 2009 | Thank you for the suggested references. We have reviewed these citations and have included those that met our inclusion criteria.
3. Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
a. For the section on page 6 (discussion of 2 Medicare papers), there are a number of papers (Wright, Petersen, Weeks, West, Liu, Morgan) that also address this issue of choice of VA or non-VA facilities that should be incorporated.; b. Given the SOTA focus on e-health applications to improve access, all published e-health interventions (MyHealtheVet, telemedicine, nurse case management via telephone or Web) should be reviewed and included. | a. We have reviewed the suggested references and included those that met our inclusion criteria.; b. We have included studies of e-health applications if they met our inclusion criteria and presented data regarding the impact of the intervention on a measure of access (objective, subjective, or satisfaction with access).
4. Additional comments
This is a good paper on an important topic. It is even more important now that the VA has mandated 14 day access to all clinics. This mandate makes it even more important to carefully understand the literature and its limitations. | Thank you.
I strongly feel there needs to be much more attention to the quality of studies synthesized in this paper. I would like some summary for each section of the types and quality of the studies contributing data to the discussion. There seems to be little discrimination between RCTs and cross-sectional studies as an example ---- no clear sense of guidance from the authors on how the reader should weight the study findings. | We agree and have added information about study type and quality.
I believe that “wait times” and “distance from the VA” should be considered separately – one is controlled by the VA and one is controlled by the patient. It seems to me that all of the studies evaluating patient health outcomes and their association with distance from the VA (or any other medical system) are almost meaningless. Unless the studies very carefully control for health status, SES, patient choices, etc., the findings are not useful, other than for the evaluation of access. It is impossible to know whether patients more distant from medical care are similar to those that are closer. Patients choose where they live for complex reasons some of which could be controlled for if assessed but some which might not ever be able to be accounted for in an observational study. If this body of literature includes studies that attempted to control for other factors, the authors need to describe this and weight the studies by their attempts to control for these potential confounders. On the other hand, waiting times are within the control of the VA and are much less likely to be confounded by patient factors. I feel strongly that each of these categories should be a subsection relating to key questions 1 and 1a. In addition to better descriptions/weighting of the studies, these issues should be more fully explored in the discussion. | Thank you for the suggestion. However, in light of the suggestion to include other barriers/facilitators, we modified the response to KQ1 to highlight factors other than distance and wait time. We organized the section by clinical area. We have rated the quality of the included studies and control of potential confounding factors was an important consideration in assigning the quality rating.
I consistently find putting the summary of findings at the beginning of a section awkward and confusing. The summary should come at the end, not the beginning of a section. | We moved the summary of findings to the end of each section.
The data on copayments seems fairly strong yet is not discussed much if at all in the discussion. This seems like fairly good and important data that could make a difference to patient care at the VA. | We agree and we added a discussion of the copayment studies to both the conclusions and future research sections.
For KQ1, I recommend describing the literature you found under each subsection. For example, it the “system-level outcomes” section, I think it would be much easier to follow the studies if you describe what you found for these types of studies there rather than in the literature summary paragraph on page 4 that precedes this section. I would like to know more about these 17 studies. Were they cross-sectional, prospective or retrospective cohort studies, or RCTs and what was their quality? I would like to know how many of each of these contribute to the section. It might even make sense to divide KQ1 into 2 parts rather than include both system level and patient level outcomes in one KQ. Few of the studies contribute to both outcomes. | Thank you for the suggestion. We have added information about study design and quality to the text.
I would like to see more epidemiologic thought in the discussion. The issue of more care equating to with improved care deserves a little more discussion than it was given. The Weinberger paper should be discussed more fully in this regard. | Thank you for the suggestion. We expanded our discussion of the issue as to whether more care equates with better care and reference Weinberger 1996 as an example.